# SUMMARY AND DISCUSSION

Physical activity is universally endorsed as a cornerstone for maintaining optimal physical and cognitive health.45,46 Increased physical activity is also considered an important therapeutic modality for patients with many chronic conditions including diabetes,47 arthritis,48 various cancers,49 obesity,50 and depression.51 Despite the proven benefits and widespread public health and clinical calls to increase physical activity, sedentary behavior has proven difficult to change.

Self-monitoring is a key behavioral strategy to increase physical activity, and objective self-monitoring, as opposed to self-report, is considered the gold standard.52 Pedometers have been found to be associated with significant increases in physical activity and significant decreases in both body mass index and blood pressure.53 Although pedometers are a cost-effective tool, they are increasingly being replaced by accelerometers. Accelerometers offer the advantage of assessing accelerative movements, in all directions. In addition, accelerometers can detect differences in intensity13 and can be tethered with other electronic devices to provide real-time, tailored feedback. Therefore this review sought to identify and summarize the evidence on the use of accelerometers on 2 major outcomes associated with many chronic conditions: physical activity and weight loss or maintenance. In addition, we sought to examine the effects of accelerometer use on satisfaction with healthcare.

We identified 14 unique RCTs that assessed the impact of accelerometers on physical activity and weight loss or maintenance. All included studies were published in the last 10 years, indicating the relatively new use of motion sensing devices in studies aimed at promoting physical activity or weight loss. Although we searched for wearable motion sensing technologies in general, no studies included newer wearable motion sensing technologies (eg, GPS, hand gesture, eye gesture, hand swipe) beyond an accelerometer. Twelve studies assessed the impact of accelerometers on physical activity and 11 on weight. No identified studies reported on the impact of accelerometers on satisfaction with healthcare. Four trials explicitly recruited older adults, 5 recruited obese/sedentary adults, 3 recruited participants with a chronic medical illness (diabetes, metabolic syndrome, COPD), and 2 recruited healthy volunteers. No studies specifically recruited Veterans.

## STRENGTH OF EVIDENCE

Table 8 presents an overview of findings and strength of evidence (SOE) by major outcomes. We found moderate SOE for small increases in physical activity level (SMD 0.29; 95% CI 0.03 to 0.55) and small decreases in weight (MD -1.44 kg; 95% CI -3.08 to 0.19) over 3- to 12-month periods (median 5.5 months) when interventions that integrated accelerometers were compared with weak or inactive controls. We found low SOE for very small increases in physical activity levels (SMD 0.17; 95% CI -1.09 to 1.43) and small decreases in weight (MD range -3.60 to -2.10 kg) for accelerometer interventions compared with active control conditions.

Table 8 Summary of Intervention Effects and Strength of Evidence Ratings

Outcome and Comparison | Number of Studies (Subjects) | Domains and Ratings Pertaining to SOE | SOE and Summary Effect Estimate (95% CI)
Physical Activity: Inactive Comparator | 9 (1279) | Risk of Bias: All RCTs, but some limitations due to poor study quality. Majority of RCTs were judged to be at high (n=5) or unclear (n=2) ROB. This domain was not rated as high ROB because 2 of the larger studies were at low ROB, and a large proportion (59.1%) of the weight for the subgroup summary estimate was generated from these 2 studies. | Moderate SMD 0.29 (0.03 to 0.55)
Physical Activity: Inactive Comparator | 9 (1279) | Consistency: Some inconsistency. The individual study estimates for the most part had the same direction of effect as the subgroup summary estimate. One study, which was the largest and judged to be at low ROB, had an individual effect size on the opposite side of the null value. The magnitude of effect sizes varied across individual studies (SMD range -0.11 to 1.22). | Moderate SMD 0.29 (0.03 to 0.55)
Physical Activity: Inactive Comparator | 9 (1279) | Directness: Direct | Moderate SMD 0.29 (0.03 to 0.55)
Physical Activity: Inactive Comparator | 9 (1279) | Precision: Some imprecision. Most of the included studies had small sample sizes. The subgroup summary estimate was precise and similar to the overall summary estimate. The impact of bias on heterogeneity was inconclusive, as there was no consistency in the relationship between studies of variable ROB and direction of effect, and the effect estimate from the largest study, scored at low ROB, was on the opposite side of the null. | Moderate SMD 0.29 (0.03 to 0.55)
Physical Activity: Active Comparator | 3 (109) | Risk of Bias: All RCTs, but all studies judged to be at high ROB. | Low SMD 0.17 (-1.09 to 1.43)
Physical Activity: Active Comparator | 3 (109) | Consistency: Minor inconsistency. Two of the 3 individual estimates had a similar effect size, but the range of individual effect sizes varied substantially from -0.05 to 0.80. | Low SMD 0.17 (-1.09 to 1.43)
Physical Activity: Active Comparator | 3 (109) | Directness: Direct | Low SMD 0.17 (-1.09 to 1.43)
Physical Activity: Active Comparator | 3 (109) | Precision: Imprecise. All of the included studies had small sample sizes. The subgroup summary estimate and the overall summary estimate had wide confidence intervals. The impact of bias on heterogeneity could not be ruled out, as one of the individual estimates was on the opposite side of the null and was judged to be at high ROB. This may have influenced heterogeneity and subsequently the overall summary estimate confidence interval. | Low SMD 0.17 (-1.09 to 1.43)
Weight: Inactive Comparator | 9 (1505) | Risk of Bias: All RCTs, but some limitations due to poor study quality. Most studies were judged to be at high (n=4) or unclear (n=3) ROB. This domain was not rated as high ROB because 2 of the larger studies were scored at low ROB, and a large proportion (49.6%) of the weight for the subgroup summary estimate was generated from these 2 studies. | Moderate MD -1.44 kg (-3.08 to 0.19)
Weight: Inactive Comparator | 9 (1505) | Consistency: Consistent in direction and magnitude. The individual estimates for the active comparator group were on the same side of the null value. Aside from one study, the MDs were consistent in magnitude when compared to the subgroup summary estimate. | Moderate MD -1.44 kg (-3.08 to 0.19)
Weight: Inactive Comparator | 9 (1505) | Directness: Direct | Moderate MD -1.44 kg (-3.08 to 0.19)
Weight: Inactive Comparator | 9 (1505) | Precision: Precise. A few of the included studies had small sample sizes, which contributed to imprecision. The subgroup summary estimate was precise and similar to the overall summary estimate. The impact of bias on heterogeneity is possible, as one study judged to be at unclear ROB was outside the MD range of other included studies in this subgroup. | Moderate MD -1.44 kg (-3.08 to 0.19)
Weight: Active Comparator | 2 (79) | Risk of Bias: Both studies RCTs, but both judged to be at high ROB. | Low MD range: -3.60 kg (-5.82 to -1.38) to -2.10 kg (-4.30 to 0.10)
Weight: Active Comparator | 2 (79) | Consistency: Minor inconsistency. The individual studies had similar MDs on the same side of the null value. | Low MD range: -3.60 kg (-5.82 to -1.38) to -2.10 kg (-4.30 to 0.10)
Weight: Active Comparator | 2 (79) | Directness: Direct | Low MD range: -3.60 kg (-5.82 to -1.38) to -2.10 kg (-4.30 to 0.10)
Weight: Active Comparator | 2 (79) | Precision: Some imprecision. Both included studies had small sample sizes. | Low MD range: -3.60 kg (-5.82 to -1.38) to -2.10 kg (-4.30 to 0.10)

Abbreviations: CI=confidence interval; MD=mean difference; SMD=standardized mean difference; RCTs=randomized controlled trials; ROB=risk of bias; SOE=strength of evidence

## SUMMARY OF EVIDENCE BY KEY QUESTION

Overall, we found a small positive effect of accelerometers on increasing physical activity and decreasing weight. Twelve studies provided estimates for the effect of accelerometers on level of physical activity. Pooled estimates demonstrated a small and favorable impact on increasing physical activity levels (SMD 0.26; 95% CI 0.04 to 0.49) with moderate heterogeneity (I^2^=64.7%). In stratified analysis by type of comparator, the effects versus the inactive comparator were similar; however, no significant effect was found when accelerometers were compared with an active comparator. A similar pattern was observed for the 11 studies that provided estimates for the effect of accelerometers on weight loss. The overall pooled estimates demonstrated a small and favorable impact on weight (MD -1.65 kg; 95% CI -3.03 to -0.28) but exhibited high heterogeneity (I^2^=81%). In stratified analysis by type of comparator, effects were muted when accelerometer interventions were compared with more robust controls than with weaker controls. The moderate to high heterogeneity in these pooled estimates may be driven by several intervention characteristics, including the duration of the interventions, intensity of adjunctive interventions (eg, accelerometer only vs brief device-driven feedback vs intensive device-driven behavioral counseling and feedback) and study design features that resulted in most studies being judged to be at high or unclear ROB. For physical activity outcomes, an additional source of heterogeneity may stem from the substantial variability in the mode (self-report vs objectively measured) and metrics (step counts per day vs minutes per day active) used to measure this outcome.

We also sought to explore the variable impact of wearable activity devices on physical activity and weight by multiple single factors that may contribute to heterogeneity (recruited populations, role of device relative to other motivational enhancement strategies, location of device on body as a proxy for ease of use). None of these individual factors was a robust predictor of heterogeneity. Thus, the variability in pooled estimates is likely due to a combination of factors related to underlying differences in populations, comparators, interventions, and study design and quality issues. However, other quantitative patterns were observed. In general, interventions that capitalized on the self-monitoring and tailored activity device-driven feedback capabilities of these devices were associated with greater decreases in weight loss. Effects were even greater when these strategies were paired with behavioral counseling focused on device feedback. The same trend was not consistently seen for greater increases in physical activity with better implementation of device feedback and self-monitoring functionality. Lastly, while we sought to explore the role of adherence to the activity device as a moderator of effects, only 4 studies provided any data on adherence to the device, and none of these studies reported such analyses. Instead, these studies focused largely on the process measures related to accelerometer adherence. In general, these studies reported a consistent pattern of decline in participants' use of activity devices over time.

## CLINICAL AND POLICY IMPLICATIONS

Commercially available wearable activity devices have surged in popularity in recent years, including accelerometers marketed for their ability to assist individuals who want to increase their physical activity. Accelerometers have proven to be a valid and reliable means of tracking step counts and activity levels; however, their effectiveness as an agent of behavior change has been less clear. Also it is unclear whether accelerometers offer additional advantages over pedometers as a means of self-monitoring physical activity.

The results of this review provide important new information by demonstrating a small positive effect of wearable accelerometers on increasing physical activity and decreasing weight. These findings are important for both clinician and policymakers who may be considering programs to encourage more widespread use of these technologies as a public health strategy to improve health and well-being. Although we found small but significant effects related to activity device use, the heterogeneity of the included studies precludes firm conclusions about how they can be deployed most effectively in clinical practice as a tool to facilitate increased physical activity. Furthermore, we did not find any studies that sought to integrate physical activity data from wearable accelerometers into the patient's medical records to facilitate ongoing primary care and chronic disease management. Such research could be of real value to clinicians and policymakers.

No studies actively recruited Veterans and, germane to the VA healthcare system, we found surprisingly few trials (n=3) that focused on chronic disease populations. Use and effectiveness of wearable accelerometers may differ among participants who are motivated to use these devices to achieve different goals; for example, those who are trying to increase physical activity to reduce pain from osteoarthritis compared to participants whose goal is to lose weight. Thus, it is unclear if these devices should be offered to all patients or a subset of patients who may derive the most benefits from increased physical activity.

For accelerometers to function optimally, patients need to wear the devices and understand the information they receive from them. In this review, we found limited data on activity device adherence. Other research suggests that more than half of individuals who purchase a wearable activity device stop using it; of these, one-third stop in the first months.54 Future research should (1) measure how often participants wear accelerometers; (2) measure how participants interact with their generated data; and (3) explore facilitators and barriers to adoption of wearable technologies. This would be valuable for clinicians, policymakers, and organizations by helping programs target individuals who are most likely to wear and therefore benefit from these devices. Last, accelerometers are more costly than traditional pedometers, which may impact decisions regarding purchase and usage. In this review, we were unable to assess whether accelerometers increase physical activity beyond pedometers.

## LIMITATIONS

Our review has a number of strengths, including a protocol-driven design, a comprehensive search, and careful quality assessment. We conducted both quantitative and qualitative synthesis when possible. Our review—and the literature—have limitations: the number of studies is small; many had design limitations (8 of 14 were judged to be at high ROB); the range of interventions evaluated was diverse; and the number and reporting of studies precluded any analyses of variability in accelerometers by more than one variable at a time. Our review was limited to English-language publications, but the likelihood of identifying relevant data unavailable from English-language sources is low.

The small sample sizes of most included trials and the populations recruited also limited our findings and may have resulted in a type II error as a result. No studies actively recruited Veterans, yet we did identify 3 studies among those with chronic medical illnesses, 5 studies among overweight/obese/sedentary populations, and 4 studies among older adults. It is likely that the results of these studies are highly applicable to the VA, because these conditions and populations are common among the patients seen in the VA healthcare system. However, having so few studies with large sample sizes leaves unanswered questions of feasibility of integrating accelerometers into clinics and healthcare systems with large, heterogeneous patient populations and multiple providers.

Many of our pooled analyses suggested moderate to high heterogeneity. While we conducted subgroup analysis to explore multiple single factors that may contribute to heterogeneity (recruited populations, role of activity devices relative to other motivational enhancement strategies, location of device on body as a proxy for ease of use), none of these individual factors was a robust predictor of heterogeneity. Thus, the observed heterogeneity is likely attributable to a combination of factors that relate to underlying differences in populations, comparators, interventions, and study design and quality issues. The overall low number and small size of included trials per outcome precluded us from conducting multivariable analyses.

## RESEARCH GAPS/FUTURE RESEARCH

This comprehensive review of the literature identified several gaps in the current evidence that warrant future investigation. We used the framework recommended by Robinson et al55 to identify gaps in evidence and classify why these gaps exist (Table 9). This approach considers the PICOTS (population, intervention, comparator, outcome, timing, and setting) to identify gaps and classifies them as due to (1) low strength of evidence or imprecise information, (2) biased information, (3) inconsistency or unknown consistency, and (4) not the right information. VA and other healthcare systems should consider their clinical and policy needs when deciding whether to invest in research to address gaps in evidence.

Table 9 Evidence Gaps and Future Research

Evidence Gap | Reason | Type of Studies to Consider
Population
- Absence of trials that actively recruited Veterans; - Limited studies (n=3) among those with chronic medical illnesses | Insufficient information | - RCTs; - Quasi-experimental studies; - Prospective cohort studies
Interventions
- What are the optimal adjunctive interventions that enhance functionally of accelerometers in motivating behavior change?; - How does intensity or dose of adjunctive interventions enhance functionally of accelerometers in motivating behavior change?; - How is adherence to use of the activity device associated with key outcomes? Are there strategies to enhance adherence?; - How do aspects of the activity device (location on body, ease of use, ability to pair with other technologies) impact physical activity and weight?; - Is accelerometer-based feedback inferior, equivalent, or superior to pedometer-based feedback for increases in physical activity or decreases in weight? | Insufficient information | - RCTs of head-to-head comparisons of different types of adjunctive intervention packages; - Stepped and adaptive trial designs
Comparators
- Relatively few studies that used active or more robust comparators; - No studies that assessed accelerometers vs pedometers | Insufficient information | - RCTs; - RCTs of head-to-head comparisons of accelerometers and pedometers
Outcomes
Uncertain effects on:; - Patient satisfaction with healthcare; Limited information on:; - Physical activity; - Weight loss or maintenance; - Adherence to devices over time | Insufficient information | - RCTs; - Prospective cohort studies; - Non-randomized controlled before-and-after studies; - Secondary analyses of existing trial data
- None of these studies examined factors that impact accelerometer adherence. Future research aimed at identifying individual characteristics associated with accelerometer adherence will inform efforts to create a hierarchy of who is more likely to adhere to these devices.; - Determine how participants interact with their generated data as feedback.; - Explore facilitators and barriers to adoption of wearable activity devices. | Insufficient information | - RCTs; - Prospective or retrospective cohort studies; - Non-randomized controlled before-and-after studies; - Qualitative studies; - Secondary analyses of existing trial data
Setting
- No studies that recruited through clinical settings | Insufficient information | - RCTs; - Prospective or retrospective cohort studies; - Nonrandomized controlled before-and-after studies

Abbreviation: RCTs=randomized controlled trials

## CONCLUSIONS

Overall this review found low to moderate strength of evidence that the use of wearable accelerometers produces small positive effects on physical activity and weight. These changes, however, may not result in clinically significant changes to health-related outcomes. The small number of studies with small sample sizes and the moderate to high heterogeneity limit the conclusions that may be drawn. What appears evident is that accelerometers may be necessary—but not sufficient—to change behavior. Unfortunately, the data available for this review did not allow us to determine the most effective means of using wearable accelerometers to facilitate behavior change. Nevertheless, we observed qualitatively that studies with more robust effects used adjunctive interventions (eg, tailored feedback and behavioral counseling) to foster motivation, had longer intervention durations, and compared accelerometers to weaker controls. Focusing on specific goals, using evidence-based strategies, personalizing designs, and integrating social support are additional, critical components for achieving increased physical activity or reduced weight. Stepped and adaptive trial designs, as well as those that incorporate patient preferences, may be particularly well-suited to address questions about the effectiveness of accelerometers within the context of complex behavioral interventions to increase physical activity and other related health outcomes.56,57

The overall paucity of studies that used accelerometers and the generally low quality of the included trials may be due, in part, to the only recent availability of accelerometers with visible displays to allow for self-monitoring and the ability to interface with behavioral programs (ie, ability to collect and share data in real time). This review raises a number of important questions and illuminates key gaps in the evidence. This includes a need to understand whether accelerometers outperform traditional pedometers, how activity device features may enhance adherence and outcomes, and the effects on long-term outcomes. The relatively low response rates and attrition trends over time from the included studies in this report underscore the importance of integrating these devices in tailored, patient-focused behavioral interventions that offer dynamic content, real-time and personalized behavioral counseling, and progressive goal-setting.

These findings are important for both clinicians and policymakers who may be considering programs to encourage more widespread use of these technologies as a public health strategy to improve health and well-being. Although we found small significant effects related to activity device use, the heterogeneity of the included studies precludes firm conclusions about how they can be deployed most effectively in clinical practice as a tool to facilitate increased physical activity. Furthermore, we did not find any studies that sought to integrate physical activity data from wearable accelerometers into the patient's medical records to facilitate ongoing primary care and chronic disease management.