# RESULTS

## LITERATURE FLOW

The literature search (Figure 1), which was limited to RCTs published between January 1, 2000, and January 6, 2015, identified 4787 unique citations from a combined search of MEDLINE (via PubMed; n=3334), Embase (n=839), CINAHL (n=265), SPORTDiscus (n=245), and Cochrane CENTRAL (n=104). After applying inclusion/exclusion criteria at the title-and-abstract screening level, 176 full texts were retrieved for further review. Of these, papers describing 14 unique RCTs were retained for data abstraction.

Figure 1 Literature Flow Chart

## CHARACTERISTICS OF INCLUDED STUDIES

Within the 14 included trials, women comprised 62.5% of the populations, median age was 49.7 years (range 28.7 to 79.8 years), and only 4 trials reported race. The majority of trials were conducted in the United States (n=8) and were sponsored either wholly or partially by government agencies (n=9). Study sizes ranged from 20 to 544 participants (median 62), with the majority of studies (n=8) randomizing fewer than 70 participants. All included studies were published in the last 10 years, indicating the relatively new use of these activity devices in studies aimed at promoting physical activity. While we searched for any wearable nonpedometer devices, all identified trials used some form of accelerometer-based motion sensing technology. Characteristics of the individual studies are described in Appendix C. A search of ClinicalTrials.gov identified one completed but unpublished trial that we believe would meet our inclusion criteria (NCT00544245), revealing a small degree of publication bias.

Twelve studies reported on outcomes related to physical activity,30,34-44 and 11 on outcomes related to weight.28-30,35-41,43 No studies assessed the outcome of satisfaction with healthcare. Four trials were conducted on older adults, 5 on overweight/obese/sedentary adults, 3 on participants with a chronic medical illness, and 2 on healthy volunteers. We did not identify any studies that were specific to Veterans. Comparators were active (eg, behavioral counseling) in 3 trials and inactive (eg, usual care, waitlist) in 11 trials. The accelerometer, usually worn on the waist (n=8 trials), was a major component of the intervention in 9 trials and a minor component in 5 trials. Only 4 trials examined adherence. Most studies (n=8) were judged to be at high ROB, with 4 studies at unclear ROB, and only 2 at low ROB.

Interventions varied widely. The duration of interventions ranged from 12 to 52 weeks, and the number of planned interactions with participants in the accelerometer conditions ranged from none to 52 weekly contacts. Trials used a wide variety of adjunctive interventions in conjunction with accelerometers, including intensive diet, weight, and physical activity behavioral counseling; tailored written feedback; and web-based supportive educational modules. Selected details of interventions and comparators for each study are provided in Table 3.

Table 3 Description of Interventions and Comparators

Study | Intervention | Comparator
Greene, 2013^39^ | 6 months of access to online social network to post about weight and physical activity progress + continuous accelerometer use and feedback | Inactive: Printed lifestyle guidelines on diet and exercise
Koizumi, 2009^42^ | 12 weeks of accelerometer with feedback + goal-setting | Inactive: 12 weeks of blinded accelerometer use
Luley, 2014^28^ | 3-arm study (2 interventional): [underlined: Intervention arm 1:] 1-time 2-hour instruction on diet and physical activity + 12 months of accelerometer use + 52 weekly individual letters with feedback on weight, diet, and physical activity [underlined: Intervention arm 2:] 1-time 2-hour instruction on diet and physical activity + 12 months of accelerometer use + 12 monthly behavioral counseling calls | Inactive: 1-time 1-hour session, consisting of diet education, diet regimen, and physical activity education
Nicklas, 2014^35^ | 5-month weight loss intervention that included: hypocaloric diet (2 prepared meals a day) + 4 days/week supervised exercise + self-regulatory intervention that involved wearing an accelerometer, documenting activity, and 6 weekly sessions of behavioral counseling | Active: 5-month weight loss intervention consisting of diet education and regimen (individualized hypocaloric intake), physical activity education, structured exercise (supervised treadmill), and in-person counseling
Paschali, 2005^44^ | 12 weeks of continuous accelerometer use and feedback + 4 monthly in-person exercise behavioral counseling sessions + workbook | Active: 12-week blinded accelerometer use with 4 monthly in-person counseling sessions to review exercise diary, a 24-page information book and home-based walking plan with physical activity education, behavioral self-management, weight goal-setting, and chronic disease monitoring
Polzien, 2007^30^ | 3-arm study (2 interventional): [underlined: Intervention arm 1:] Continuous technology-based behavioral weight control program: 7 in-person individualized counseling sessions over 12 weeks + 12 weeks of continuous accelerometer use and feedback [underlined: Intervention arm 2:] Intermittent technology-based behavioral weight control program: 7 in-person individualized counseling sessions over 12 weeks + 3 weeks of accelerometer use and feedback over 12 weeks | Active: 7 in-person individualized counseling sessions consisting of diet education, diet regimen (1200 to 1500 kcal/day; dietary fat <20% of total energy intake), physical activity education, and weight goal-setting
Reijonsaari, 2012^41^ | 12 months of continuous accelerometer use and feedback + access to telephone counseling (frequency not defined) | Inactive: Explanation of results of physical exams and information on physical activity and occupational healthcare
Shrestha, 2013^40^ | 1-time 1.5-hour lifestyle instruction + 6 months of continuous accelerometer use and feedback | Inactive: Self-directed exercise and/or U.S. Army-mandated physical training
Shuger, 2011^29^ | 4-arm study (3 interventional) : [underlined: Intervention arm 1:] Group-based behavioral weight loss: 14 group weight loss sessions + 6 individual phone calls + workbook over 9 months [underlined: Intervention arm 2:] Accelerometer alone: 9 months of continuous accelerometer use and feedback [underlined: Intervention arm 3:] Group-based behavioral weight loss + accelerometer use: 9 months of continuous accelerometer use and feedback + 14 group weight loss sessions + 6 individual phone calls + workbook | Inactive: Self-directed weight loss manual with diet education, physical activity education, and weight goal-setting
Slootmaker, 2009^43^ | 3 months of continuous accelerometer use + tailored physical activity feedback and motivational tips via web-based portal | Inactive: A single written brochure with brief physical activity recommendations
Tabak, 2014^34^ | Self-directed technology-supported care program that included a tailored web-based exercise program, accelerometer-based activity senor and motivational messaging, COPD self-management module, and as needed web-portal teleconsultation conducted over 9 months | Inactive: Usual care
Thompson, 2014^38^ | 12 weeks of continuous accelerometer use and feedback + weekly brief counseling sessions on increasing activity + treadmill desk | Inactive: 12 weeks of blinded accelerometer use
Thompson, 2014^36^ | 24 weeks of continuous accelerometer use and feedback + weekly brief telephone counseling sessions focused on accelerometer feedback + 6 in-person brief counseling sessions | Inactive: 24 weeks of blinded accelerometer use
Wijsman, 2013^37^ | 12 weeks of continuous accelerometer use and feedback + personal website + personal e-coach who gives updates on activity status and advice via web portal | Inactive: 3-month waitlist control

Abbreviation: COPD=chronic obstructive pulmonary disease

## KQ 1 AMONG ADULTS, WHAT IS THE EFFECTIVENESS OF WEARABLE MOTION SENSING TECHNOLOGIES ON: (A) PHYSICAL ACTIVITY LEVELS; (B) WEIGHT LOSS OR MAINTENANCE; (C) PATIENT SATISFACTION WITH HEALTHCARE?

### Key Points

- We identified 12 studies (2 judged to be at low ROB, 2 at unclear ROB, and 8 at high ROB) that met eligibility criteria comparing an accelerometer intervention for increasing physical activity outcomes. The majority of the included studies (n=9) compared the accelerometer device against a weak inactive comparator consisting of usual care, waitlist controls, or one-time educational interventions.
- The overall summary estimate (SMD 0.26; 95% CI 0.04 to 0.49) demonstrated a small positive effect of accelerometer interventions on physical activity levels that was statistically significant. When stratified by comparator, a small statistically significant effect (SMD 0.29; 95% CI 0.03 to 0.55) was found for accelerometer interventions on the outcome of increasing physical activity when compared to an inactive control. An effect of smaller magnitude but same direction was found for the active comparator group, but the pooled estimate was not statistically significant (SMD 0.17; 95% CI -1.09 to 1.43).
- Eleven trials (2 judged to be at low ROB, 3 at unclear ROB, and 6 at high ROB) examined the impact of accelerometer interventions on weight loss or maintenance. Nine of these studies used a weak/inactive comparator. The overall pooled estimate demonstrated a small but statistically significant effect (MD -1.65 kg; 95% CI -3.03 to - 0.28) of accelerometers on weight loss. Stratified results by inactive comparator mirrored the overall results but were not statistically significant (MD -1.44 kg; 95% CI -3.08 to 0.19). Only 2 studies used active comparators; both demonstrated a positive trend of weight loss, but only one study was statistically significant.
- The large number of trials at high or unclear ROB, small number of participants in the majority of the trials, and moderate to high heterogeneity across summary estimates limits the strength of evidence on the impact of accelerometers on physical activity levels and weight loss or maintenance.

### Physical Activity (KQ 1a)

#### Synthesis of Findings

Twelve studies, (2 judged to be at low ROB,37,41 2 at unclear ROB,34,38 and 8 at high ROB30,35,36,39,40,42-44) examined the impact of accelerometers on the outcome of physical activity. There was substantial variability in the mode and metrics of scales used to measure physical activity. Therefore, all summary estimates were calculated as SMDs. We stratified results by comparator type (inactive vs active) and present stratified and overall pooled estimates. The inactive comparator group contained 9 studies (1279 participants; 2 studies judged to be at low ROB,37,41 5 at high ROB,36,39,40,42,43 and 2 at unclear ROB34,38). The active comparator group contained only 3 small studies, all judged to be at high ROB (n=109 participants).30,35,44

Figure 2 shows the forest plot of the meta-analysis examining the effect of accelerometers on physical activity with an overall pooled estimate and stratified pooled estimates by inactive and active comparator subgroups. The overall pooled estimate indicated a small, statistically significant effect for interventions using accelerometers to increase physical activity (SMD 0.26; 95% CI 0.04 to 0.49) with a high amount of heterogeneity (I^2^ =64.7%). A similar small effect was found for interventions using accelerometers to increase physical activity when compared to an inactive comparator (SMD 0.29; 95% CI 0.03 to 0.55). This summary estimate had high heterogeneity (I^2^=70.3%). The high heterogeneity in these pooled estimates may be driven by several intervention characteristics including the duration of the interventions and the intensity of adjunctive interventions (eg, accelerometer only vs brief device-driven feedback vs intensive device-driven behavioral counseling and feedback), which underscore the overall heterogeneity across these intervention approaches.

Figure 2 Effect of Accelerometer Interventions on Physical Activity

Abbreviations: CI=confidence interval; SMD=standardized mean difference

There was also a very small positive overall effect (SMD 0.17; 95% CI -1.09 to 1.43) that was not statistically significant for accelerometer devices when compared to an active comparator. This summary estimate had moderate heterogeneity (I^2^=52.3%). All of the studies included in this analysis were judged to be at high ROB.

#### Summary of Findings

We identified 12 studies that assessed the impact of accelerometer interventions on physical activity. Nine of these used weak controls consisting of usual care, waitlists, or one-time educational instruction and were categorized as using inactive comparators. The other 3 studies used more robust comparators and were classified as having active comparators. Compared to inactive control, the impact of accelerometer interventions on physical activity was similar to that observed in the overall summary estimate, favoring a small effect of accelerometer interventions on physical activity. Both the stratified and overall summary estimates displayed high heterogeneity as assessed by I^2^ values >50%.

While the 3 trials with active comparators demonstrated a positive trend of increasing physical activity, the negligible pooled summary estimate (SMD 0.17; 95% CI -1.09 to 1.43) was not statistically significant. When compared to the inactive control summary estimate, these findings suggest that accelerometers may not have as substantial an impact on increasing physical activity when compared to a more robust and active comparator. However, the small number of studies, small sample sizes within these studies, and moderate to high heterogeneity limit conclusions that may be drawn.

### Weight Loss or Maintenance (KQ 1b)

#### Synthesis of Findings

Eleven trials (2 judged to be at low ROB,37,41 3 at unclear ROB,28,29,38 and 6 at high ROB30,35,36,39,40,43) examined the impact of accelerometers on weight loss or maintenance. All but one study reported weight changes in kilograms (kg). The other study39 reported weight changes in pounds, which we converted to kilograms. Thus, all summary estimates were calculated as changes in weight expressed in kilograms. We stratified results by comparator type (inactive vs active) and present stratified and overall pooled estimates. The inactive comparator group contained 9 studies (n=1505 participants; 4 studies judged to be at high ROB,36,39,40,43 3 at unclear ROB,28,29,38 and 2 at low ROB37,41). The active comparator group contained only 2 small studies judged to be at high ROB (n=79 participants).30,35

Figure 3 shows the forest plot of the meta-analysis examining the effect of the accelerometer interventions on weight loss or maintenance. Only the inactive comparator group had sufficient studies to be pooled. Compared to inactive controls, the impact of accelerometer interventions on weight loss was similar to that observed in the overall summary estimate (MD -1.44 vs -1.65 kg, respectively). Thus, both the overall and stratified estimate favored a small impact of accelerometer interventions on weight loss. However, the inactive pooled estimate was not statistically significant. Both the stratified and overall summary estimates displayed high heterogeneity as assessed by I^2^ values >80%. High heterogeneity in these pooled estimates is likely driven by several intervention characteristics including the duration of the interventions and intensity of adjunctive interventions (eg, accelerometer only vs brief device-driven feedback vs intensive device-driven behavioral counseling and feedback) and underscores the overall heterogeneity across these intervention approaches.

Figure 3 Effect of Accelerometer Interventions on Weight Loss or Maintenance

Abbreviations: CI=confidence interval; MD=mean difference

Two small trials judged to be at high ROB compared interventions that used accelerometers with active comparators.30,35 While both trials demonstrated a positive trend of weight loss (MD range -3.60 to -2.10), only one study35 was statistically significant. Differences in results are likely attributable to differences in the intensity of other intervention strategies used in conjunction with accelerometer use and in the duration of the interventions. The study with statistically significant findings35 used structured and supervised exercise training, meal preparation twice daily, and behavior counseling delivered over 5 months. The study that did not produce statistically significant results was only 12 weeks long and used behavioral counseling only in conjunction with accelerometer use.30

#### Summary of Findings

We identified 11 studies that assessed the impact of accelerometer interventions on weight loss or maintenance. Nine of these used weak control conditions consisting of usual care, waitlists, or one-time educational instruction, and were categorized as using inactive comparators. Two studies used more robust comparators and were classified as having active comparators. While both trials with active comparators demonstrated a positive trend of weight loss (MD range -3.60 to -2.10), only one study was statistically significant. Differences in results are likely attributable to differences in the intensity of other intervention strategies used in conjunction with accelerometer use and in the duration of interventions. Compared to inactive controls, the impact of accelerometer interventions on weight loss was similar to that observed in the overall summary estimate, favoring a small impact of accelerometer interventions on weight loss. However, the inactive pooled estimate was not statistically significant. Both the stratified and overall summary estimates displayed high heterogeneity as assessed by I^2^ values >80%. High heterogeneity in these pooled estimates are likely driven by several intervention and population characteristics that underscore the overall variability across these studies.

In the active comparator group, most studies demonstrated a small weight loss that ranged from -0.36 to -2.65 kg. Yet, one study demonstrated a large weight loss of -8 kg (95% CI -10.41 to -5.59).28 This trial evaluated the effects of telemonitoring for management of obesity over 12 months in patients with established metabolic syndrome. Both the control and intervention groups received dietary instruction at the beginning of the trial. The intervention group also received accelerometers and feedback via monthly behavioral counseling calls. Study authors posited that the magnitude of weight loss seen was secondary to the design of the intervention. The active interventions included key strategies associated with successful weight loss such as self-monitoring, counselor feedback and communication, social support, a structured program, and the use of an individually tailored program. Indeed, other studies included in the pooled analysis that included tailored feedback delivered by a coach or device were more likely to be associated with statistically significant weight loss.36,37

### Patient Satisfaction (KQ 1c)

No studies reported on this outcome.

### Quality of Evidence for KQ 1

#### Risk of Bias

Figure 4 presents a summary of the evaluation of the ROB, which shows an ROB graph with review authors' judgments about each ROB item presented as percentages across all included studies.

Figure 4 Risk of Bias Graph^a^ a For the overall score, low ROB required random sequencing, allocation concealment, and blinding in order to be scored low risk with no other important concerns; unclear ROB was assigned if 1 or 2 domains were scored not clear or not done; high ROB was assigned if >2 domains were scored not clear or not done.

Abbreviation: PA=physical activity

#### Selection Bias

##### Random Sequence Generation

Across all included studies, treatment allocation was described as random, and no studies were judged to be at high ROB in this domain. However, 7 of the 14 trials (50.0%) did not give details about the method for generating the random sequence, resulting in a rating of unclear ROB.

##### Allocation Concealment

In 5 of the 14 trials (35.7%), methods for allocation concealment were described in sufficient detail to determine whether the intervention allocation could have been foreseen in advance of or during enrollment, resulting in a judgment of low ROB. In the majority of trials (9 of 14 [64.3%]), there was an unclear ROB due to inadequate detail about allocation concealment provided by authors.

#### Performance Bias

For the outcome of physical activity, the blinding of participants and personnel was highly variable, as there are challenges to blinding physical activity interventions. Of the 12 trials measuring physical activity as an outcome, only 2 were judged to be at low ROB as a result of adequate reporting of blinding. In 7 of 12 trials (58.3%), there was an unclear ROB due to inadequate information regarding blinding. One study was judged to be at high ROB due to lack of blinding.

Similar to physical activity outcomes, for the weight outcome, the blinding of participants and personnel was highly variable, as there are challenges to blinding weight change interventions. Of the 11 trials measuring weight change as an outcome, 4 (36.4%) were judged to be at low ROB as a result of adequate reporting of blinding. In 6 of 11 trials (54.5%), there was an unclear ROB due to inadequate information regarding blinding. One study was judged to be at high ROB due to lack of blinding.

Satisfaction with healthcare was not identified as an outcome in any of the included studies. Therefore, no ROB is reported for this outcome.

#### Detection Bias

For the outcome of physical activity, in 5 of the 12 trials (41.7%) there was sufficient information provided by the authors regarding outcome blinding assessment to judge this domain as low ROB. In the remaining trials (7 of 12 [58.3%]), insufficient information regarding outcome blinding assessment was provided by authors, resulting in a judgment of unclear ROB.

For the outcome of weight, 6 of the 11 trials (41.7%) gave sufficient information provided by the study authors about outcome blinding assessment to judge this domain to be at low ROB. In the remaining trials (4 of 11 [36.4%]), insufficient information regarding outcome blinding assessment was provided by authors, resulting in a score of unclear ROB.

Satisfaction with healthcare was not identified as an outcome in any of the included studies. Therefore, no ROB is reported for this outcome.

#### Attrition Bias

All trials reported the numbers randomized to each group. The majority of trials (13 of 14 [92.9%]) reported complete outcome data that included information on attrition and exclusions from analysis. One trial did not disclose the reason for attrition/exclusion in sufficient detail, resulting in a judgment of high ROB.

#### Reporting Bias

The majority of trials (12 of 14 [85.7%]) reported details of the measured outcomes sufficient to be judged to be at low ROB.

#### Other Bias

The majority of trials (11 of 14 [78.6%]) provided sufficient details not to raise concerns about bias of a nature not covered within the other domains mentioned. Two trials did not provide sufficient methodological detail to judge this domain and were given a judgment of unclear ROB, whereas one trial was judged to be at high ROB stemming from use of a questionable analytical approach during the interim analysis and stopping the trial due to insignificant results.

#### Overall Risk of Bias

Overall ROB was assessed for each included study (Figure 5). The majority of studies (8 of 14 [57.1%]) were judged to be at high ROB, 4 (28.6%) were at unclear ROB, and only 2 studies (14.3%) were judged to be at low ROB.

Figure 5 Risk of Bias Summary: Review Authors' Judgments About Risk of Bias Items for Each Included Study^a^ a For the overall score, low ROB required random sequencing, allocation concealment, and blinding in order to be scored low risk with no other important concerns; unclear ROB was assigned if 1 or 2 domains were scored not clear or not done; high ROB was assigned if >2 domains were scored not clear or not done.

Abbreviation: PA=physical activity

## KQ 2 AMONG ADULTS, DOES THE IMPACT OF WEARABLE MOTION SENSING TECHNOLOGIES VARY BY: (A) CHARACTERISTICS OF THE POPULATION; (B) TYPE OF ADJUNCTIVE INTERVENTIONS; (C) ADHERENCE TO USE OF THE DEVICES; OR (D) CHARACTERISTICS OF THE DEVICE?

### Key Points

We explored the variable impact of wearable motion sensing technologies (activity devices) on physical activity and weight by multiple single factors that may contribute to heterogeneity (ie, recruited populations, role of device relative to other motivational enhancement strategies, location of device on body as a proxy for ease of use). None of these individual factors was a robust predictor of heterogeneity.

- Across 4 population subgroups (overweight/obese/sedentary, older adults, healthy volunteers, and chronic medical illnesses), there were no major subpopulation differences in the magnitude and direction of effect estimates on physical activity or weight. Only the older adult subgroup for physical activity and the overweight/obese/sedentary subgroups for weight displayed relatively lower heterogeneity.
- The impact of accelerometer interventions was not well-explained by the role of the device, operationalized as major role versus minor role of the accelerometer in the overall intervention approach. Pooled estimates mirrored the results of the overall summary estimate. The direction and magnitude of the effects were similar for both major and minor role groups; subgroups displayed moderate to high heterogeneity.
- Only 4 of 14 studies reported on adherence to the activity device, and these reports largely focused on the process measures related to accelerometer adherence (hours the device was worn, uploads to websites). The role of accelerometer adherence as a moderating factor of outcome remains to be fully examined in the literature.
- The predominant location of accelerometers was on the waist, followed by the arm. The impact of accelerometer interventions was not well explained by activity device characteristics operationalized as location of the device on the body. Pooled results on physical activity and weight were similar to the overall summary estimate.

### Variation by Population Characteristics (KQ 2a)

#### Synthesis of Findings

We classified studies and organized findings by physical activity and weight. While satisfaction with healthcare was also an outcome of interest, no study reported on this outcome. We planned to perform meta-analytic regression to assess the impact of population characteristics on the outcomes of interest, but we had insufficient studies to perform these analyses. Thus, we categorized studies into population subgroups as determined by study trial recruitment criteria (ie, overweight/obese/sedentary, older adults, healthy volunteers, and chronic medical illnesses). For each subgroup with 3 or more studies, we calculated summary estimates. Other results are synthesized qualitatively.

##### Physical Activity

To assess whether the effects of accelerometer interventions vary by population characteristics, we conducted exploratory subgroup analyses based on study eligibility criteria. For the overweight/obese/sedentary population, there were 158 participants in 4 studies. All 4 studies were judged to be at high ROB.30,38,40,43 For older adults, there were 393 participants in 4 studies, including one study judged to be at low ROB,37 one at unclear ROB,36 and 2 at high ROB.35,42 For healthy volunteers, there were 783 participants in 2 studies, with one study each at low41 and high39 ROB. For chronic medical illnesses, there were 54 participants in 2 studies, with one study each at unclear34 and high44 ROB.

Figure 6 shows the forest plot of the meta-analysis examining the effect of accelerometer interventions on physical activity by the population subgroups. We had sufficient studies to pool effects for 2 population subgroups—the overweight/obese/sedentary population and older adults. Both subgroups displayed a similar magnitude and direction of effect—namely, a small positive effect of accelerometer interventions on increased physical activity—but neither estimate was statistically significant. The pooled SMD was 0.35 (95% CI -0.52 to 1.22) for the overweight/obese/sedentary group and displayed moderate heterogeneity (I^2^=51.3%). For the older adult subgroup, the pooled SMD was 0.34 (95% CI -0.11 to 0.80), with low heterogeneity (I^2^=38.0%).

Figure 6 Effect of Accelerometer Interventions on Physical Activity by Population Characteristics

Abbreviations: CI=confidence interval; SMD=standardized mean difference

Two additional subgroups—healthy volunteers39,41 and those with chronic medical illnesses34,44—were evaluated in only 2 studies each and therefore could not be pooled. Results were mixed in the 2 studies in healthy volunteers. The differences between the 2 studies were likely due to differences in the population baseline activity levels and in participant interactions with adjunctive interventions. In a study at low ROB,41 healthy insurance company employees (n=521 total) receiving a combined accelerometer and counseling intervention did not increase physical activity when compared to a control group (SMD -0.11; 95% CI -0.28 to 0.06). At baseline, the majority of employees in both arms met physical activity guidelines. In a study judged to be at high ROB,39 there was a small effect indicating increased physical activity (SMD 0.30; 95% CI 0.05 to 0.54) in 262 healthy employees and family members of PeaceHealth Oregon who used an intervention containing an accelerometer plus an online social network versus an education-only control group. The level of social interaction was much greater in the intervention using an online social network compared with the intervention with online or telephone counseling.

For the 2 studies in chronic medical illness populations, accelerometer interventions produced no significant effect on physical activity in one study judged to be at unclear ROB34 (SMD 0.00; 95% CI -0.80 to 0.80), and a moderate statistically significant effect on physical activity in the other study, which was at high ROB44 (SMD 0.80; 95% CI 0.06 to 1.55). These differences were likely due to differences in populations (chronic obstructive pulmonary disease [COPD]34 vs type 2 diabetes44) and interventions, with one intervention more focused on physical activity.44 In the COPD study34 24 participants received either usual care or a telehealth program where an accelerometer plus a smartphone activity coach was one of 4 components. The intervention arm did not increase physical activity; however, adherence to the physical activity portion of the program was low compared with the portion focused on COPD self-management. In the type 2 diabetes study (n=30 participants),44 accelerometers plus counseling increased physical activity as compared to counseling alone.

##### Weight

For the outcome of weight, we conducted subgroup analyses by the following populations based on study eligibility criteria: overweight/obese/sedentary populations (1170 participants, 5 studies, with 4 at high ROB30,38,40,43 and one at unclear ROB29); older adults (315 participants, 3 studies at low,37 high,35 and unclear36 ROB); healthy volunteers (870 participants, 2 studies at high39 and low41 ROB); and chronic medical illness populations (120 participants, 1 study at unclear ROB28). There were insufficient studies to pool results for healthy volunteers and chronic medical illness populations.

Figure 7 shows the forest plot displaying the effects of accelerometer interventions on weight by the population subgroups. Among overweight/obese/sedentary persons, 5 studies assessed the impact of accelerometer interventions on change in weight in kilograms. Compared with inactive and active control conditions combined, accelerometer interventions resulted in an MD of -1.22 kg (95% CI -2.46 to 0.02). This estimate displayed relatively low heterogeneity (I^2^=26.8%). In older adults, accelerometer interventions produced a decrease in weight of a similar magnitude. Again, the pooled effect estimate was not statistically significant (MD -1.08 kg; 95% CI -5.22 to 3.06) and displayed high heterogeneity (I^2^=74.4%). This heterogeneity likely reflected populations somewhat different in age and other study eligibility criteria (eg, also recruiting for other comorbidities such as overweight).

Figure 7 Effect of Accelerometer Interventions on Weight (in Kilograms) by Population Characteristics

Abbreviations: CI=confidence interval; MD=mean difference

We identified only 2 studies in healthy volunteers,39,41 and both showed a small positive effect of accelerometer interventions on weight. In one study at high ROB,39 262 healthy employees and family members of PeaceHealth Oregon participated in an intervention with accelerometers where the major focus was on developing an online social network for sharing goal-setting and attainment. When compared to control, this intervention produced an MD of -1.63 kg (95% CI -2.48 to -0.78). In the other study, at low ROB,41 when compared to a control intervention, a combined accelerometer and counseling intervention produced an MD of -0.50 kg (95% CI -1.00 to 0.00) in health insurance company employees. As above, baseline physical activity was higher in the latter study, and the intensity of the social component of the intervention was greater in the former.

One study judged to be at unclear ROB assessed the effect of accelerometer interventions on weight among study participants with chronic medical illnesses.28 Persons with metabolic syndrome were randomized to a one-time education-only control or 12 months of accelerometer use plus weight, diet, and physical activity feedback via monthly telephone calls or weekly letters. More weight loss was observed in the accelerometer condition than in the control arm (MD -8.00 kg; 95% CI -10.41 to -5.59).

#### Summary of Findings

##### Physical Activity

For subgroups where quantitative analyses were performed (overweight/obese/sedentary and older adults), pooled effect sizes were not statistically significant (SMD 0.35; 95% CI -0.52 to 1.22 and SMD 0.34; 95% CI -0.11 to 0.80), but were of similar magnitude and direction when compared to one another and to the overall summary estimate. For subgroups where only qualitative analyses could be performed (healthy and chronic medical illness), there were 2 studies each with mixed results. For both subpopulations, one study showed a small, statistically significant increase in physical activity, while the other showed little to no effect that was not statistically significant. Thus, taken together, all subgroups support a small positive effect, with no apparent differential effectiveness on physical activity.

##### Weight

For the outcome of weight loss, there were no major differences in effect sizes across the 4 population subgroups with the exception of the chronic medical illness subgroup, where a single study at high ROB showed a larger effect size (MD -8.00 kg; 95% CI -10.41 to -5.59). This difference might be attributed to the metabolic syndrome population studied, in which counseling convention strongly promotes lifestyle change above pharmacologic interventions. Additionally, this intervention was focused on weight loss and included counseling and monitoring of nutrition—as well as physical activity and weight—over a 12-month period compared to a weak control of a one-time educational intervention.

##### Summary

Table 4 provides a summary of findings for KQ 2a.

Table 4 Summary of Findings: Variation by Population Subgroups (KQ 2a)

Outcome | Population
Outcome | Overweight/Obese/Sedentary | Older Adults | Healthy Volunteers | Chronic Medical Illnesses
Physical activity | 4 studies: SMD 0.35 (95% CI -0.52 to 1.22) | 4 studies: SMD 0.34 (95% CI -0.11 to 0.80) | 2 studies: SMD range: -0.11 to 0.30 | 2 studies: SMD range: 0.00 to 0.80
Weight | 5 studies: MD -1.22 kg (95% CI -2.48 to 0.02) | 3 studies: MD -1.08 kg (95% CI -5.22 to 3.06) | 2 studies: MD range: -1.63 to -0.50 kg | 1 study: MD -8.00 kg (95% CI -10.41 to -5.59)

Abbreviations: CI=confidence interval; MD=mean difference; SMD=standardized mean difference

### Variation by Activity Device Role (Major vs Minor; KQ 2b)

#### Synthesis of Findings

We classified studies and organized findings by physical activity and weight. While satisfaction with healthcare was also an outcome of interest, no study reported on this outcome. We categorized studies into subgroups as determined by activity device role (major or minor). A device was determined to have a major role if the device (accelerometer) was the only or central motivational enhancement intervention intended to improve the primary outcome of the study. In this case, other intervention components were centered on the feedback provided by the accelerometer. Other adjunctive interventions may have been included but played a minor role in enhancing physical activity or could not have been conducted without the feedback of accelerometer data. An activity device was determined to have a minor role if the accelerometer was an integrated component of a suite of other motivation enhancement interventions which may have included, but were not limited to, a structured exercise program, diet counseling/education, chronic disease counseling/monitoring, and/or self-management techniques.

##### Physical Activity

To assess whether the effects of the accelerometer interventions on physical activity vary by activity device role, we conducted an exploratory subgroup analysis by major versus minor role of the device. The major role subgroup contained 8 studies (n=1041 participants), 5 judged to be at high rob,30,40,42-44 one at unclear ROB,36 and 2 at low ROB.37,41 The minor role subgroup contained 4 studies (n=374 participants), 3 at high ROB35,38,39 and one at unclear ROB.34

Figure 8 shows the forest plot of the meta-analysis examining the effect of accelerometer interventions on physical activity by activity device role. Both subgroups displayed a similarly small, positive effect size for accelerometer interventions on increased physical activity, but neither group was statistically significant. The pooled SMD was 0.26 (95% CI -0.02 to 0.54) for the major device role subgroup and displayed high heterogeneity (I^2^=71.6%). The subgroup including studies where the activity device played a minor role showed a pooled SMD of 0.28 (95% CI -0.43 to 1.00), with moderate heterogeneity (I^2^=43.2%).

Figure 8 Effect of Accelerometer Interventions on Physical Activity by Device Role

Abbreviations: CI=confidence interval; SMD=standardized mean difference

##### Weight

To assess whether the effects of the accelerometer interventions on weight vary by activity device role, we conducted an exploratory subgroup analysis by major role versus minor role of the device. In the major role subgroup, there were 8 studies (n=1174 participants), 3 judged to be at high ROB,30,40,43 2 at low ROB,37,41 and 3 at unclear ROB.28,29,36 In the minor role subgroup, there were 3 studies (n=410 participants), all at high ROB.35,38,39

Figure 9 shows the forest plot of the meta-analysis examining the effect of the interventions on weight by activity device role. The direction and magnitude of the effects were similar for both groups, favoring a small impact of less than 2 kg of weight loss, but neither group was statistically significant. Compared with inactive and active control conditions combined, the pooled MD was -1.47 kg (95% CI -3.47 to 0.53) for the major role subgroup and displayed high heterogeneity (I^2^=83.1%). The minor role subgroup showed a pooled MD of -1.99 kg (95% CI -4.10 to 0.12) and displayed low heterogeneity (I^2^=24.2%).

Figure 9 Effect of Accelerometer Interventions on Weight (in Kilograms) by Device Role

Abbreviations: CI=confidence interval; MD=mean difference

#### Summary of Findings

The impact of accelerometer interventions on physical activity and weight were not well-explained by the role of the activity device, operationalized as major role versus minor role of accelerometer in the overall intervention approach. These estimates mirrored the results of the overall summary estimate. For physical activity, 8 studies were categorized as using accelerometers as the major intervention strategy,30,36,37,40-44 and 4 were categorized as using accelerometers as a minor component in the overall intervention approach.34,35,38,39 For weight loss, 8 studies were categorized as major28-30,36,37,40,41,43 versus 3 categorized as minor.35,38,39 The direction and magnitude of the effects were similar for both subgroups, favoring a small positive impact on increasing physical activity and decreasing weight that mirrored the overall summary estimate. Yet neither group was statistically significant. Across physical activity and weight loss, the major subgroups displayed high heterogeneity. High heterogeneity in the major role of device subgroup is likely driven by several intervention characteristics that underscore the overall variability in the intervention approaches included in this subgroup. For example, studies in this group ranged from accelerometer-alone strategies29 to interventions that included in-person behavioral counseling and accelerometer-driven feedback used to enhance the self-monitoring and motivational aspects of device feedback.30 In general, interventions that included an accelerometer as a major component of the intervention and that capitalized on the self-monitoring and tailored device-driven feedback capabilities of these devices were associated with a greater decrease in weight (see Figure 9).28-30 The same trend was not seen for greater increases in physical activity with better implementation of activity device feedback and self-monitoring functionality.

Table 5 provides a summary of findings for KQ 2b.

Table 5 Summary of Findings: Variation by Device Role (KQ 2b)

Outcome | Role of Accelerometer
Outcome | Major Role | Minor Role
Physical activity | SMD 0.26 (95% CI -0.02 to 0.54) | SMD 0.28 (95% CI -0.43 to 1.00)
Weight | MD -1.47 kg (95% CI -3.47 to 0.53) | MD -1.99 kg (95% CI -4.10 to 0.12)

Abbreviations: CI=confidence interval; MD=mean difference; SMD=standardized mean difference

### Variation by Adherence to Use of the Activity Device (KQ 2c)

#### Synthesis of Findings

The primary aim of KQ 2c was to examine accelerometer adherence as a moderator of the outcomes of physical activity, weight loss, and satisfaction with healthcare. Only 4 of 14 studies reported any measure of accelerometer adherence.30,35,41,43 Across these 4 studies, adherence to the activity device was defined variably by total arm-band time use, categorical measure of time the device was worn (eg, often vs regularly), percentage of days device was worn at least 10 hours per day, and change in web-based service use at 2 time points. In light of dropout rates (range of 12% to 31%), adherence data were reported only on study completers. While these 4 studies assessed physical activity levels and body weight as outcome measures, only one of these studies examined accelerometer adherence relationship to these outcomes (weight only). Satisfaction with healthcare was not assessed as an outcome in any of these studies. Individual determinants of accelerometer adherence were not examined in any of these studies. The synthesis of findings presented here combines results for physical activity and weight loss outcomes.

A large worksite physical activity promotion study judged to be at low ROB41 randomized 544 employees to either 12 months of continuous accelerometer use and distance counseling (by phone or the web) or a control group that received baseline fitness results only. Participants in the intervention arm were instructed to enter their physical activity score from the accelerometer manually to the web-based service. Use of the web-based service was assessed as a proxy of accelerometer adherence in this study. Overall, use of the web-based service was low among participants in the intervention arm, averaging just 15 logins during the last 6 months of the trial (0.6 logins per week). Comparisons of the 0- to 6-month versus 6- to 12-month time periods of the study show that use of the web-based service also decreased over the trial for both participants and coaches. Participants entered fewer days of physical activity scores (14% of days vs 9% of days), coaches sent fewer messages to participants (7.2 vs 6.1 messages), and participants sent fewer messages to coaches (4.3 vs 1.7 messages). This study did not examine the impact of accelerometer adherence on physical activity or weight loss outcomes.

A second, smaller worksite physical activity promotion study judged to be at high ROB43 randomized 102 healthy young employees to either 3 months of continuous accelerometer use and tailored web-based support or a control group that received a single brochure with brief activity recommendations at baseline. Participants in the intervention arm were encouraged to enter their physical activity score from the accelerometer manually to the web-based service. Uploaded accelerometer scores were paired with automatic, tailored physical activity advice and motivational tips. Seventy-three percent of those in the intervention arm reported wearing the accelerometer “regularly” or “often” and accessed the web-based service on average nearly once per week to upload accelerometer data. Fifty-two percent of intervention arm participants set a personal goal using the web-based service. However, 41% of participants found the tailored advice on the website unappealing. Barriers to compliance included a limited menu of preferred personal activities on the web-based service, and physical activity advice not relevant to the participant's preferred personal activity. This study did not examine the impact of accelerometer adherence on physical activity or weight loss outcomes.

In a small 12-week behavioral weight-loss study judged to be at high ROB,30 57 healthy adult participants were randomized to: (1) standard in-person weight control program; (2) standard program + continuous technology-based behavioral program (continuous armband-accelerometer wear and feedback); or (3) standard program + intermittent technology-based behavioral program (3 weeks of armband accelerometer wear and feedback). Average total accelerometer wear time was low in both the intermittent and continuous groups (63.8 minutes/week and 71.0 minutes/week, respectively) and was highly variable (range 51 to 350 minutes/week). Adherence to the accelerometer, defined as total arm band time, declined significantly across all 4-week time periods in the continuous technology group. Self-monitoring of exercise also decreased across the intervention period in the standard and intermittent groups. This was the only study to examine the relationship between accelerometer adherence and weight loss. Significant correlations were reported between change in body weight and total accelerometer wear time in both the intermittent (r=-0.68, p<0.01) and continuous (r=-0.71, p<0.01) technology arms.

In a pilot study (high ROB) of spontaneous physical activity and weight loss,35 48 older adults were randomized to a 5-month weight loss intervention that included a hypocaloric diet and aerobic exercise or the same weight loss intervention plus a self-regulatory intervention (which included an accelerometer) to promote spontaneous physical activity. Following post-weight loss assessments at 5 months, both groups transitioned to a self-directed diet and exercise program during a 5-month follow-up period. Adherence to the accelerometer was high (see Table 6). Eighty-five percent of participants (n=17) submitted accelerometer data for the entire 10 months of the study, of which 87% wore the accelerometer for the prescribed ≥10 hours per day. Eighty-one percent of participants met the daily spontaneous physical activity goal recorded by the accelerometer. Reported barriers to accelerometer wear compliance included device malfunction/battery change (13%), illness/health (9%), forgot to wear the monitor (7%), and too busy/time conflict (7%). The transition from the 5-month, intensive intervention to the self-monitored program also seemed to pose a barrier for some who stopped wearing the monitor (15%). This study did not examine the impact of accelerometer adherence on physical activity or weight loss outcomes.

Table 6 Summary of Findings: Accelerometer Adherence Across Individual Studies of Physical Activity and Weight Loss (KQ 2c)

Study | Role of Accelerometer | Accelerometer Adherence Description
Nicklas, 2014^35^ | Minor | - 85% of participants submitted accelerometer data for entire 10 months; - 87% of days completers wore accelerometer at least 10 hours/day; - 81% of days spontaneous physical activity goal met; - Barriers to compliance: device malfunction/battery change (13%), illness/health (9%), forgot to wear (7%), too busy/time conflict (7%)
Polzien, 2007^30^ | Major | - Accelerometer wear time was low and highly variable in both continuous and intermittent technology groups; - Significant decline in total accelerometer wear time use by continuous technology group across all 4-week time periods; - Standard and intermittent groups decreased self-monitoring of exercise across the 12-week intervention period; - Longer total accelerometer wear time was significantly associated with greater weight loss in both the continuous and intermittent technology groups
Reijonsaari, 2012^41^ | Major | - Use of web-based service decreased with time (comparing 0 to 6-month vs 6- to 12-month study periods) for both participants and coaches; - Declines in web-based service across time included entries of participant physical activity scores (14% of days vs 9% of days); coach communication to participants (7.2 vs 6.1 messages); participant communication to coaches (4.3 vs 1.7 messages)
Slootmaker, 2009^43^ | Major | - 73% of participants wore accelerometer “often” or “regularly”; - 52% of participants set personal goal on web-based service; - Barriers to compliance: Limited menu of preferred, personal activities on web-based service; physical activity advice not relevant to participant-preferred, personal activity; 41% found advice on website unappealing

#### Summary of Findings

Only 4 of 14 studies provided any data on adherence to the activity device. Although our primary aim was to examine accelerometer adherence as a moderator of physical activity, weight loss, and satisfaction outcomes, none of these studies reported such analyses. Instead, these studies focused largely on the process measures related to accelerometer adherence. Despite the major role played by the accelerometer in 3 of these studies, a consistent pattern of decline in participants' use of the device was evident over study duration, and generally low levels of adherence over time were reported. Two studies conducted in workplace settings showed significant participant disengagement expressed in low levels of self-motivated, self-initiated, stated goals to be achieved during the study time period. In summary, we are unable to determine from this literature whether accelerometer adherence has an effect on the outcomes of interest when accelerometers are used as part of behavioral interventions.

Table 6 provides a summary of findings for KQ 2c.

### Variation by Characteristics of the Activity Device (Body Location; KQ 2d)

#### Synthesis of Findings

We classified studies and organized findings by physical activity and weight. While satisfaction with healthcare was also an outcome of interest, no study reported on this outcome. We categorized studies into subgroups as determined by characteristics of the activity device, operationalized as location of the device on the body. Locations of interest were waist, arm, wrist, and multisite. One study that did not specify device location was not included. We had sufficient studies to pool effects only for one subgroup (waist); other results are synthesized qualitatively.

##### Physical Activity

To assess whether the effects of the accelerometer interventions on physical activity vary by device characteristics, we conducted exploratory subgroup analysis by the following device location sites: waist (n=809 participants; 7 studies, 5 judged to be at high ROB,35,38,42-44 one at low ROB,41 and one at unclear ROB36); arm (n=38 participants; 2 studies, both at high ROB30,40); wrist (n=235 participants; one study at low ROB37); and multisite (n=24 participants; one study at unclear ROB34).

Figure 10 shows the forest plot examining the effect of the interventions on physical activity by activity device location. The pooled estimate displayed a weakly positive association regarding effect of location of accelerometer at the waist on increasing physical activity (SMD 0.24; 95% CI. -0.15 to 0.63) and moderate heterogeneity (I^2^=62.3%). This effect was similar in direction and magnitude to the overall summary estimate.

Figure 10 Effect of Accelerometer Interventions on Physical Activity by Device Location

Abbreviations: CI=confidence interval; SMD=standardized mean difference

Three additional subgroups—arm, wrist, and multisite—contained fewer than 3 studies and could not be pooled. The 2 studies where the device was worn on the arm30,40 showed mixed results, neither of which was statistically significant. Of the 2 studies, one (at high ROB)30 showed a negative impact on physical activity (SMD -0.15; 95% CI -0.78 to 0.49). The second (also at high ROB)40 showed a small positive effect on physical activity (SMD 0.60; 95% CI -0.30 to 1.50). The differences in the 2 studies were likely due to differences in the duration of the intervention (12 vs 24 weeks), comparator arms (active vs weak or active vs active), and overall analytic strategy of each study. Of note, both studies had high dropout rates, but only one study specifically stated that they used an intention-to-treat analysis. In Shrestha et al40 an accelerometer paired with an interactive website versus usual care did not show a statistically significant mean change in total physical activity between groups. The lack of difference in effect on physical activity was attributed to low initial recruitment (28 participants total) and a high dropout rate (attrition 64% at 6 months). Polzien et al30 used a technology-based program added to an in-person behavioral weight loss program. Although each group showed a significant increase in leisure time physical activity, there was no statistically significant difference between the active intervention arms.

For one study where the accelerometer was worn on the wrist (low ROB),37 the intervention produced a modestly statistically significant increase in physical activity (SMD 0.56; 95% CI 0.30 to 0.82). In this study, 119 adults were randomized to receive a 12-week web-based physical activity program focused on increasing daily activity. The intervention was composed of 3 elements: an accelerometer-based activity monitor, a personal website, and a personal e-coach who gave feedback about ways to increase physical activity. After 13 weeks, daily physical activity increased in the intervention versus control group (11% vs 5%, p <0.11).

Finally, a pilot study (at unclear ROB)34 showed no effect on physical activity of an accelerometer that could be worn at multiple sites as compared to a usual care group (SMD 0.00; 95% CI -0.80 to 0.80). The intervention arm included 4 modules: a web-based exercise program for home exercising, an activity coach with real-time feedback, self-management of COPD exacerbations via diary on web portal, and teleconsultation. The activity coach consisted of an accelerometer-based sensor and a smartphone that displayed cumulative activity and sent motivational cues based on activity already performed. Objective activity at baseline and 3 months for the intervention group (n=15) was 536.3 (standard error of the mean [SEM] 42.6) and 511.0 (SEM 44.1), respectively. Objective activity at baseline and 3 months for usual care (n=14) was 360.5 (SEM 44.7) and 335.2 (46.3), respectively. The notable baseline difference may be influenced by the poorer clinical characteristics including a higher prevalence of dyspnea among usual care (p=0.03) despite computerized randomization distributed in sealed envelopes.

The lack of difference in physical activity based on multisite location is likely secondary to very low use of the exercise module by physiotherapists and low use and adherence to the exercise module and activity coach by participants. Of note, median adherence to prescribed exercise schemes was 21%.

##### Weight

To assess whether the effects of the accelerometer interventions on weight vary by device characteristics, we conducted exploratory subgroup analysis by the following device location sites: waist (n=852 participants; 6 studies, 3 judged to be at high ROB,35,38,43 one at low ROB,41 and 2 at unclear ROB28,36); arm (n=157 participants; 3 studies, 2 at high30,40 and one at unclear29 ROB); and wrist (n=226 participants; one study at low ROB37).

Figure 11 shows the forest plot of the meta-analysis examining the effect of the interventions on weight by device location. The overall pooled estimate demonstrated a small statistically significant effect on weight (MD -1.65 kg; 95% CI -3.03 to -0.28), with high heterogeneity (I^2^=81%). We had sufficient studies to pool effects for 2 subgroups (waist and arm). Both produced effects of the same direction and magnitude, which mirrored those of the overall summary estimate. Compared with control conditions, the pooled MD was -2.01kg (95% CI -4.99 to 0.97) for the waist subgroup and displayed high heterogeneity (I^2^=89.1%). High heterogeneity in the waist subgroup is likely driven by differences in intervention approach (self-monitoring vs self-monitoring plus individualized counseling/feedback), intensity (weekly counseling via phone calls or letters vs self-driven interaction with device/website), and length of follow up (range 3 to 12 months). The arm location subgroup showed a similar pooled MD of - 2.08 kg but was statistically significant (95% CI -4.13 to -0.02), with low heterogeneity (I^2^=0.00%).

Figure 11 Effect of Accelerometer Interventions on Weight (in Kilograms) by Device Location

Abbreviations: CI=confidence interval; MD=mean difference

One additional subgroup, wrist, contained fewer than 3 studies and could not be pooled but demonstrated small positive impacts on weight loss. In the one study (low ROB) where the accelerometer was worn on the wrist,37 the intervention produced a small impact on weight (MD -0.67 kg; 95% CI -1.33 to -0.01). In this study, 119 adults were randomized to receive either a 12-week web-based physical activity program focused on increasing daily activity or a 3-month waitlist control. The intervention was composed of 3 elements: an accelerometer-based activity monitor, a personal website, and a personal e-coach who gave feedback about ways to increase physical activity.

#### Summary of Findings

The predominant location of accelerometers was the waist, followed by the arm. The impact of accelerometer interventions was not well explained by where the device was worn on the body; pooled estimates mirrored those of the overall summary estimate. For physical activity, activity devices worn on the waist (n=7 studies) produced effects that ranged from negative and not statically significant to modest positive effects that were statistically significant. Of note, only one small (n=20) study of a waist-worn device, judged to be at high ROB, produced positive and statistically significant effects on physical activity.38 Activity devices worn on the arm (n=2 studies) also displayed mixed results. One study (at low ROB) including a wrist-worn device37 produced a positive and statistically significant impact on physical activity, while a study that allowed multisite use34 showed no impact on physical activity.

For weight loss, activity devices worn on the waist (n=6 studies) produced effects that ranged from no effect to positive and statistically significant effects. High heterogeneity in the waist subgroup is likely driven by differences in intervention approach (self-monitoring vs self-monitoring plus individualized counseling/feedback), intensity (weekly counseling via phone calls or letters vs self-driven interaction with device/website), and differences in length of follow up (range 3 to 12 months). Activity devices worn on the arm (n=3 studies) displayed modestly positive effects on weight that were statistically significant and displayed low heterogeneity. One study including a wrist-worn device produced a small positive and statistically significant effect on weight. This was the only device location that produced positive and statistically significant effects on both physical activity and weight, but this group included only one study (low ROB).37

Table 7 provides a summary of findings for KQ 2d.

Table 7 Summary of Findings: Variation by Characteristics of the Device (KQ 2d)

Outcome | Location of Accelerometer
Outcome | Waist | Arm | Wrist | Multisite
Physical activity | 7 studies: SMD 0.24 (95% CI -0.15 to 0.63) | 2 studies: SMD range: -0.15 to 0.60 | 1 study: SMD 0.56 (95% CI 0.30 to 0.82) | 1 study: SMD 0.00 (95% CI -0.80 to 0.80)
Weight | 6 studies: MD -2.01 (95% CI -4.99 to 0.97) | 3 studies: MD -2.08 (95% CI -4.13 to -0.02) | 1 study MD -0.67 (95% CI -1.33 to -0.01) | No studies

Abbreviations: CI=confidence interval; MD=mean difference; SMD=standardized mean difference

### Quality of Evidence for KQ 2

The same 14 studies were included for KQs 1 and 2. The quality of evidence is discussed above, under KQ 1.