# REFERENCES

1 U.S. Department of Health and Human Services. Physical Activity and Health: A Report of the Surgeon General. Atlanta, GA. U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion. 1996. www.cdc.gov/nccdphp/sgr/contents.htm. June 23, 2015.
2 Littman AJ, Forsberg CW, Koepsell TD. Physical activity in a national sample of veterans. Med Sci Sports Exerc. 2009;41(5):1006-1013. [pmid: 19346987].
3 Myers J. The health benefits and economics of physical activity. Curr Sports Med Rep. 2008;7(6):314-316. [pmid: 19005351].
4 Weiss JP, Froelicher VF, Myers JN, Heidenreich PA. Health-care costs and exercise capacity. Chest. 2004;126(2):608-613. [pmid: 15302750].
5 Troiano RP, Macera CA, Ballard-Barbash R. Be physically active each day. How can we know?. J Nutr. 2001;131(2S-1):451S-460S. [pmid: 11160577].
6 Sallis JF, Saelens BE. Assessment of physical activity by self-report: status, limitations, and future directions. Res Q Exerc Sport. 2000;71(2 Suppl):S1-14. [pmid: 10925819].
7 Duncan GE, Sydeman SJ, Perri MG, Limacher MC, Martin AD. Can sedentary adults accurately recall the intensity of their physical activity?. Prev Med. 2001;33(1):18-26. [pmid: 11482992].
8 Troiano RP, Berrigan D, Dodd KW, Masse LC, Tilert T, McDowell M. Physical activity in the United States measured by accelerometer. Med Sci Sports Exerc. 2008;40(1):181-188. [pmid: 18091006].
9 Steeves JA, Murphy RA, Crainiceanu CM, Zipunnikov V, Van Domelen DR, Harris TB. Daily patterns of physical activity by type 2 diabetes definition: comparing diabetes, prediabetes, and participants with normal glucose levels in NHANES 2003-2006. Prev Med Rep. 2015;2:152-157. [pmid: 25909051].
10 Loprinzi PD, Walker JF, Lee H. Association between physical activity and inflammatory markers among U.S. adults with chronic obstructive pulmonary disease. Am J Health Promot. 2014;29(2):81-88. [pmid: 24359176].
11 Chastin SF, Mandrichenko O, Helbostadt JL, Skelton DA. Associations between objectively-measured sedentary behaviour and physical activity with bone mineral density in adults and older adults, the NHANES study. Bone. 2014;64:254-262. [pmid: 24735973].
12 Lee J, Song J, Hootman JM, et al. Obesity and other modifiable factors for physical inactivity measured by accelerometer in adults with knee osteoarthritis. Arthritis Care Res (Hoboken). 2013;65(1):53-61. [pmid: 22674911].
13 Bassett DR Jr., Dinesh J. Use of pedometers and accelerometers in clinical populations: validity and reliability issues. Phys Ther Rev. 2010;15(3):135-142.
14 Tudor-Locke C. Taking steps toward increasing physical activity: using pedometers to measure and motivate. President's Council on Physical Fitness and Sports Research Digest. Series 3. June. 2002;(17). www.presidentschallenge.org/informed/digest/docs/200206digest.pdf. June 23, 2015.
15 Le Masurier GC, Tudor-Locke C. Comparison of pedometer and accelerometer accuracy under controlled conditions. Med Sci Sports Exerc. 2003;35(5):867-871. [pmid: 12750599].
16 Tyo BM, Fitzhugh EC, Bassett DR Jr., John D, Feito Y, Thompson DL. Effects of body mass index and step rate on pedometer error in a free-living environment. Med Sci Sports Exerc. 2011;43(2):350-356. [pmid: 20543755].
17 Lyons EJ, Lewis ZH, Mayrsohn BG, Rowland JL. Behavior change techniques implemented in electronic lifestyle activity monitors: a systematic content analysis. J Med Internet Res. 2014;16(8):e192. [pmid: 25131661].
18 Gonzalez C, Herrero P, Cubero JM, et al. PREDIRCAM eHealth platform for individualized telemedical assistance for lifestyle modification in the treatment of obesity, diabetes, and cardiometabolic risk prevention: a pilot study (PREDIRCAM 1). J Diabetes Sci Technol. 2013;7(4):888-897. [pmid: 23911170].
19 Lefebvre C, Manheimer E, Glanville J. Chapter 6: Searching for studies. Higgins JPT, Green S, editors. Cochrane Handbook for Systematic Reviews of Interventions. Version 5.1.0. (updated March 2011). The Cochrane Collaboration. 2011. www.cochrane-handbook.org. July 22, 2014.
20 Baker PR, Francis DP, Soares J, Weightman AL, Foster C. Community wide interventions for increasing physical activity. Cochrane Database Syst Rev. 2015;1. Cd008366.
21 Mansi S, Milosavljevic S, Baxter GD, Tumilty S, Hendrick P. A systematic review of studies using pedometers as an intervention for musculoskeletal diseases. BMC Musculoskelet Disord. 2014;15:231. [pmid: 25012720].
22 Mays RJ, Rogers RK, Hiatt WR, Regensteiner JG. Community walking programs for treatment of peripheral artery disease. J Vasc Surg. 2013;58(6):1678-1687. [pmid: 24103409].
23 Vaes AW, Cheung A, Atakhorrami M, et al. Effect of ‘activity monitor-based’ counseling on physical activity and health-related outcomes in patients with chronic diseases: A systematic review and meta-analysis. Ann Med. 2013;45(5-6):397-412. [pmid: 23952917].
24 De Bourdeaudhuij I, Van Dyck D, De Meester F, et al. Built environment, physical activity, and obesity. Int J Obes. 2011;35(Suppl 1):S149.
25 Bort-Roig J, Gilson N, Puig-Ribera A, Contreras R, Trost S. Measuring and Influencing Physical Activity with Smartphone Technology: A Systematic Review. Sports Med. 2014;44(5):671-686. [pmid: 24497157].
26 Bellet RN, Adams L, Morris NR. The 6-minute walk test in outpatient cardiac rehabilitation: validity, reliability and responsiveness—a systematic review. Physiotherapy. 2012;98(4):277-287. [pmid: 23122432].
27 Higgins JPT, Altman DG, Sterne JAC. Chapter 8: Assessing risk of bias in included studies. Higgins JPT, Green S, editors. Cochrane Handbook for Systematic Reviews of Interventions. Version 5.1.0. (updated March 2011). The Cochrane Collaboration. 2011. www.cochrane-handbook.org. June 23, 2015.
28 Luley C, Blaik A, Gotz A, et al. Weight loss by telemonitoring of nutrition and physical activity in patients with metabolic syndrome for 1 year. J Am Coll Nutr. 2014;33(5):363-374. [pmid: 25105874].
29 Shuger SL, Barry VW, Sui X, et al. Electronic feedback in a diet- and physical activity-based lifestyle intervention for weight loss: a randomized controlled trial. Int J Behav Nutr Phys Act. 2011;8:41. [pmid: 21592351].
30 Polzien KM, Jakicic JM, Tate DF, Otto AD. The efficacy of a technology-based system in a short-term behavioral weight loss intervention. Obesity (Silver Spring). 2007;15(4):825-830. [pmid: 17426316].
31 Cohen J. Statistical Power Analysis for the Behavioral Sciences. 2nd ed. Hillsdale, NJ. Lawrence Earlbaum Associates. 1988.
32 Viechtbauer W. Conducting meta-analyses in R with the metafor package. Journal of Statistical Software. 2010;36(3):1-48.
33 Agency for Healthcare Research and Quality. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Rockville, MD. Agency for Healthcare Research and Quality. www.effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?pageaction=displayproduct&productid=318. November 6, 2014.
34 Tabak M, Brusse-Keizer M, van der Valk P, Hermens H, Vollenbroek-Hutten M. A telehealth program for self-management of COPD exacerbations and promotion of an active lifestyle: a pilot randomized controlled trial. Int J Chron Obstruct Pulmon Dis. 2014;9:935-944. [pmid: 25246781].
35 Nicklas BJ, Gaukstern JE, Beavers KM, Newman JC, Leng X, Rejeski WJ. Self-monitoring of spontaneous physical activity and sedentary behavior to prevent weight regain in older adults. Obesity (Silver Spring). 2014;22(6):1406-1412. [pmid: 24585701].
36 Thompson WG, Kuhle CL, Koepp GA, McCrady-Spitzer SK, Levine JA. “Go4Life” exercise counseling, accelerometer feedback, and activity levels in older people. Arch Gerontol Geriatr. 2014;58(3):314-319. [pmid: 24485546].
37 Wijsman CA, Westendorp RG, Verhagen EA, et al. Effects of a web-based intervention on physical activity and metabolism in older adults: randomized controlled trial. J Med Internet Res. 2013;15(11):e233. [pmid: 24195965].
38 Thompson WG, Koepp GA, Levine JA. Increasing physician activity with treadmill desks. Work. 2014;48(1):47-51. [pmid: 24004766].
39 Greene J, Sacks R, Piniewski B, Kil D, Hahn JS. The impact of an online social network with wireless monitoring devices on physical activity and weight loss. J Prim Care Community Health. 2013;4(3):189-194. [pmid: 23799706].
40 Shrestha M, Combest T, Fonda SJ, Alfonso A, Guerrero A. Effect of an accelerometer on body weight and fitness in overweight and obese active duty soldiers. Mil Med. 2013;178(1):82-87. [pmid: 23356124].
41 Reijonsaari K, Vehtari A, Kahilakoski OP, van Mechelen W, Aro T, Taimela S. The effectiveness of physical activity monitoring and distance counseling in an occupational setting - results from a randomized controlled trial (CoAct). BMC Public Health. 2012;12:344. [pmid: 22578104].
42 Koizumi D, Rogers NL, Rogers ME, Islam MM, Kusunoki M, Takeshima N. Efficacy of an accelerometer-guided physical activity intervention in community-dwelling older women. J Phys Act Health. 2009;6(4):467-474. [pmid: 19842461].
43 Slootmaker SM, Chinapaw MJ, Schuit AJ, Seidell JC, Van Mechelen W. Feasibility and effectiveness of online physical activity advice based on a personal activity monitor: randomized controlled trial. J Med Internet Res. 2009;11(3):e27. [pmid: 19674956].
44 Paschali AA, Goodrick GK, Kalantzi-Azizi A, Papadatou D, Balasubramanyam A. Accelerometer feedback to promote physical activity in adults with type 2 diabetes: a pilot study. Percept Mot Skills. 2005;100(1):61-68. [pmid: 15773694].
45 Institute of Medicine. Cognitive Aging: Progress in Understanding and Opportunities for Action. Washington, DC. National Academies Press. 2015.
46 Pahor M, Guralnik JM, Ambrosius WT, et al. Effect of structured physical activity on prevention of major mobility disability in older adults: the LIFE study randomized clinical trial. JAMA. 2014;311(23):2387-2396. [pmid: 24866862].
47 Umpierre D, Ribeiro PA, Kramer CK, et al. Physical activity advice only or structured exercise training and association with HbA1c levels in type 2 diabetes: a systematic review and meta-analysis. JAMA. 2011;305(17):1790-1799. [pmid: 21540423].
48 Dunlop DD, Song J, Semanik PA, et al. Relation of physical activity time to incident disability in community dwelling adults with or at risk of knee arthritis: prospective cohort study. BMJ. 2014;348:g2472. [pmid: 24782514].
49 Fong DY, Ho JW, Hui BP, et al. Physical activity for cancer survivors: meta-analysis of randomised controlled trials. BMJ. 2012;344:e70. [pmid: 22294757].
50 Thorogood A, Mottillo S, Shimony A, et al. Isolated aerobic exercise and weight loss: a systematic review and meta-analysis of randomized controlled trials. Am J Med. 2011;124(8):747-755. [pmid: 21787904].
51 Herring MP, Puetz TW, O'Connor PJ, Dishman RK. Effect of exercise training on depressive symptoms among patients with a chronic illness: a systematic review and meta-analysis of randomized controlled trials. Arch Intern Med. 2012;172(2):101-111. [pmid: 22271118].
52 Burke LE, Wang J, Sevick MA. Self-monitoring in weight loss: a systematic review of the literature. J Am Diet Assoc. 2011;111(1):92-102. [pmid: 21185970].
53 Bravata DM, Smith-Spangler C, Sundaram V, et al. Using pedometers to increase physical activity and improve health: a systematic review. JAMA. 2007;298(19):2296-2304. [pmid: 18029834].
54 Nielsen Newswire. Are consumers really interested in wearing tech on their sleeves?. March. 20. 2014. www.nielsen.com/us/en/insights/news/2014/tech-styles-are-consumers-really-interested-in-wearing-tech-on-their-sleeves.html. July 2, 2015.
55 Robinson KA, Saldanha IJ, Mckoy NA. Frameworks for Determining Research Gaps During Systematic Reviews. Methods Future Research Needs Report No. 2. (Prepared by the Johns Hopkins University Evidence-based Practice Center under Contract No. HHSA 290-2007-10061-I.) AHRQ Publication No. 11-EHC043-EF. Rockville, MD. Agency for Healthcare Research and Quality. June. 2011. www.effectivehealthcare.ahrq.gov/reports/final.cfm. July 2, 2015.
56 Craig P, Dieppe P, Macintyre S, et al. Developing and evaluating complex interventions: the new Medical Research Council guidance. [Reprint in Int J Nurs Stud. 2013 May;50(5):587-92; PMID: 23159157]. BMJ. 2008;337:a1655. [pmid: 18824488].
57 Moore GF, Audrey S, Barker M, et al. Process evaluation of complex interventions: Medical Research Council guidance. BMJ. 2015;350:h1258. [pmid: 25791983].