# METHODS

## TOPIC DEVELOPMENT

The topic was nominated after a process that included a preliminary review of published peer-reviewed literature and consultation with investigators, Veterans Affairs (VA) and non-VA experts, and key stakeholders. The VA National Center for Health Promotion and Disease Prevention (NCP) nominated this project. The goal of this report, as defined by NCP, is to assess whether the VA should invest in accelerometers and other wearable activity devices as a tool to motivate Veterans to be more physically active.

The final key questions (KQs), developed in consultation with stakeholders, were:

- KQ 1: Among adults, what is the effectiveness of wearable motion sensing technologies (eg, activity devices such as accelerometer-based fitness trackers, global positioning systems [GPS]) on:
  a. Physical activity levels?
  b. Weight loss or maintenance?
  c. Patient satisfaction with healthcare?
- KQ 2: Among adults, does the impact of wearable motion sensing technologies (eg, activity devices such as accelerometer-based fitness trackers, GPS) vary by:
  a. Characteristics of the population (overweight/obese/sedentary adults, older adults, healthy volunteers, and individuals with chronic medical illnesses)?
  b. Type of adjunctive interventions (does the activity device play a major or minor role)?
  c. Adherence to use of the device?
  d. Characteristics of the device (body location—waist, arm, wrist, or multisite)

We followed a standard protocol for this review, and each step was pilot tested to train and calibrate study investigators. The PROSPERO registration number is CRD42015017343.

## SEARCH STRATEGY

In consultation with an expert librarian, we searched MEDLINE (via PubMed), Embase, CINAHL, SPORTDiscus, and Cochrane CENTRAL from January 1, 2000, to January 6, 2015, for peer-reviewed, English-language randomized controlled trials (RCTs). We used Medical Subject Heading (MeSH) terms and selected free-text terms for wearable motion sensing technologies and for activities/outcomes of interest (eg, movement, exercise therapy, physical fitness), along with validated search terms for RCTs.19 The exact search strategies used are provided in Appendix A. We further reviewed the bibliographies of included trials and systematic reviews20-26 for missed publications. To assess for possible publication bias, we searched ClinicalTrials.gov (www.clinicaltrials.gov) to identify completed but unpublished studies meeting our eligibility criteria. All citations were imported into 2 electronic databases (for referencing, EndNote^®^ Version X5, Thomson Reuters, Philadelphia, PA; for data abstraction, DistillerSR; Evidence Partners Inc., Manotick, ON, Canada).

## STUDY SELECTION

Using prespecified inclusion and exclusion criteria (Table 1), 2 trained investigators assessed titles and abstracts for relevance to the KQs. Full-text articles identified by either investigator as potentially relevant were retrieved for further review and examined by 2 investigators against the eligibility criteria. Disagreements on inclusion/exclusion were resolved by discussion or by a third investigator. In addition, trials with 3 or more arms were examined for appropriateness of all arms for inclusion. For example, data from any active arm that did not include a wearable activity device were not abstracted for inclusion in the analysis.

Table 1 Inclusion and Exclusion Criteria

Study Characteristic | Inclusion Criteria | Exclusion Criteria
Population | - Adults 18 years of age and older | - Elite athletes; - Children; - Inpatient populations; - Pregnant women
Interventions | - Studies will be included if at least one of the groups used wearable activity devices that provide objective feedback on physical activity to the wearer (eg, non-pedometer-based trackers such as accelerometer-based fitness trackers, smartphone applications, GPS-based trackers), alone or in combination with other interventions to enhance physical activity | - Pedometer-based (only) studies; - Non-wearable systems; - Systems that do not objectively monitor activity; - Systems that do not provide feedback to the wearer; - Interventions that use wearable devices to measure the effects of another intervention (eg, drugs) on ability to perform physical activity
Comparators | - Usual care/standard of care, waitlist control; - Pedometer-based interventions; - Other active comparator focused on enhancing physical activity (eg, educational or behavioral interventions | - Validation studies of head-to-head comparisons of different wearable physical activity devices used to assess validity of devices
Outcomes | - Change in physical activity behavior (eg, total steps, total activity, proportion of participants at activity goal); - Change in weight, body mass index, change or proportion of participants at goal; - Patient satisfaction with healthcare | - Any outcomes not listed
Timing | - ≥3 months postrandomization | - <3 months postrandomization
Setting | - Outpatient general medical settings (geriatrics, family medicine, general internal medicine, integrative medicine); - Specialty medical care clinics (eg, orthopedic, rheumatology, endocrine, cardiology); - Community settings | - Intervention delivered primarily in hospital inpatient setting; - Studies where monitoring of physical activity is confined to a supervised setting
Study design | - RCTs, n>20 | - Not a clinical study (eg, editorial, nonsystematic review, letter to the editor, case series); - Prospective and retrospective observational studies; - Measurement or validation studies
Publication type | - English-language only; - Peer-reviewed articles; - Published from 2000 forward | - Non-English articles; - Abstracts only

Abbreviations: GPS=global positioning system; RCTs=randomized controlled trials

## DATA ABSTRACTION

Data from included articles were abstracted into a customized database by a trained investigator and confirmed by a second investigator. Data elements included date of publication, sample size, location of study, intervention/exposure details, descriptors to assess applicability, quality elements, and outcomes. Key population and activity device characteristics abstracted were age, sex, chronic medical illness status, type of wearable activity monitor (eg, brand, location worn on body), type of adjunctive interventions (eg, behavioral weight management strategies, physical activity education) adherence to use of measurement device, and duration and frequency of intervention. Disagreements were resolved by consensus or by obtaining a third investigator's opinion when consensus could not be reached.

## QUALITY ASSESSMENT

We used the key quality criteria described in the Cochrane Collaboration Risk of Bias Tool (CCRBT). The CCRBT was designed to evaluate the risk of bias (ROB) in RCTs.27 It evaluates 6 different domains: (1) adequacy of random sequence generation; (2) allocation concealment; (3) blinding of participants and study personnel; (4) incomplete outcome data; (5) reporting bias due to selective outcome reporting; and (6) other forms of bias such as differences in relation to baseline measures, reliable primary outcomes, or protection against contamination. The Cochrane Collaboration provides guidelines to score each item. Each domain is evaluated as low ROB, unclear ROB, or high ROB. To draw conclusions about the overall ROB within trials we summarized assessments across items in the CCRBT and used the approach outlined in Table 2.

Table 2 Approach to Formulating Summary Risk of Bias for Each Outcome Across Domains

Risk of Bias | Interpretation | Criteria
Low ROB | Bias, if present, is unlikely to alter the results seriously | Adequacy of random sequence generation, allocation concealment, and blinding scored as low ROB, and no important concerns related to the other domains
Unclear ROB | ROB that raises some doubts about the results | One or 2 domains are scored “not clear” or “not done”
High ROB | Bias may alter the results seriously | More than 2 domains are scored as “not clear” or “not done”

Abbreviations: ROB=risk of bias

## DATA SYNTHESIS

When meta-analysis was feasible, we computed summary estimates of effect. We aggregated outcomes when there were at least 3 studies with the same outcome. For KQ 1, analyses were conducted separately for wearable activity device interventions versus inactive controls (eg, waitlist, usual care) and wearable activity device interventions versus active comparators (eg, group weight loss, counseling). Three trials had more than one intervention arm.28-30 Two of these trials compared different adjunctive interventions to continuous monitoring via accelerometers.28,29 For these 2 studies, we selected the intervention conditions with the less-intensive adjuncts (eg, monthly counseling vs weekly counseling). The third trial tested the impact of continuous versus intermittent accelerometer feedback.30 For this study, we selected the comparisons between continuous accelerometer use and control, as this was the type of accelerometer use evaluated in all other studies.

Continuous outcomes (difference in change from baseline to follow-up between intervention and control) were analyzed using standardized mean differences (SMDs) for physical activity outcomes and mean differences (MDs) for weight outcomes in a random-effects model with the Knapp-Hartung correction to confidence intervals. The method we used to interpret the SMD as an effect size was as follows: small effect size, SMD=0.2; medium, SMD=0.5; and large, SMD ≥0.80.^31^ We used R (R Foundation for Statistical Computing, Vienna, Austria) with the metafor package32 to calculate the summary estimates of treatment effect. We evaluated for statistical heterogeneity using visual inspection and the I^2^ statistic. Publication bias was assessed using findings from the ClinicalTrials.gov search.

We explored potential sources of heterogeneity including characteristics of the population (eg, chronic medical illness status), adherence to the use of the wearable activity device, and characteristics of the device defined as location worn on body. We aimed to assess the differential impact of type of adjunctive interventions (eg, behavioral weight management intervention, physical activity education, goal-setting) as a source of potential heterogeneity. Because type and quantity of adjunctive interventions varied greatly from study to study, we operationalized this moderator as the role of the wearable activity device (ie, major vs minor component of intervention). To be categorized as being a major component of the intervention, the wearable activity device needed to be the central motivational enhancement intervention intended to improve the primary outcome of the study. Other adjunctive interventions might be included but had to play a minor role in enhancing physical activity. To be categorized as being a minor component of the intervention, the wearable activity device needed to be an integrated component of a suite of other motivation enhancement interventions, such as a structured exercise program, diet or chronic disease counseling/education/monitoring, self-management techniques, or monetary or nonmonetary incentives. Two independent investigators categorized the role of the device, and any discrepancies were reconciled by the co-principal investigators.

If a quantitative synthesis was not feasible, we analyzed the data qualitatively. We gave more weight to the evidence from higher-quality studies with more precise estimates of effect. We focused on documenting and identifying patterns of the intervention across outcome categories. We analyzed potential reasons for inconsistency in treatment effects across studies by evaluating differences in the study population, intervention, comparator, and outcome definitions.

## RATING THE BODY OF EVIDENCE

The strength of evidence (SOE) for each KQ was assessed using the approach described in the Agency for Healthcare Research and Quality (AHRQ)'s Methods Guide for Effectiveness and Comparative Effectiveness Reviews.33 We focused on the 2 main outcomes of physical activity and weight. The AHRQ approach requires assessment of 4 domains: risk of bias, consistency, directness, and precision. Additional domains are used when appropriate: coherence, dose-response association, impact of plausible residual confounders, strength of association (magnitude of effect), and publication bias. These domains were considered qualitatively, and a summary rating of high, moderate, or low SOE was assigned after discussion by 2 investigators. In some cases, a rating of high, moderate, or low was impossible or imprudent to make. In these situations, a rating of insufficient was assigned. This 4-level rating scale consists of the following definitions:

- High—High confidence that the evidence reflects the true effect. Further research is very unlikely to change our confidence in the estimate of effect.
- Moderate—Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of effect and may change the estimate.
- Low—Low confidence that the evidence reflects the true effect. Further research is likely to change the confidence in the estimate of effect and is likely to change the estimate.
- Insufficient—Evidence either is unavailable or does not permit estimation of an effect.

## PEER REVIEW

A draft of this report was reviewed by technical experts and clinical leadership. A transcript of their comments and our responses is provided in Appendix B.