# INTRODUCTION

Participation in regular physical activity is associated with a wide range of mental and physical health benefits. Patients with diabetes, obesity, and musculoskeletal disease, in particular, derive significant benefits from regular physical activity including favorable effects on blood pressure, lipid profiles, joint swelling and pain, weight control and body fat distribution, and psychological well-being.1 Despite these known benefits, a large proportion of adults, including military Veterans, are insufficiently active. Less than 50% of Veterans report engaging in physical activity at the level to promote health.2 Comparisons also show disparities among VA users and non-users, with higher rates of physical inactivity (20%) observed among Veterans using VA services.2 This is a significant concern for VHA clinicians, managers, and policymakers given published reports showing that low aerobic fitness, stemming from inactivity, is associated with increased healthcare costs.3,4

Physical activity has previously been measured using self-reported measures (eg, questionnaires, interviews); however there are problems with self-report measures, as these measures do little to motivate or change physical activity behavior and can be subject to reporting bias.5-7 Wearable motion sensing technologies (activity monitors), such as pedometers and accelerometers, have become popular tools to overcome some of these barriers. Epidemiologic and observational studies have used activity monitors to characterize activity intensity and daily activity patterns across diverse samples.8-12 Pedometers were the first generation of activity monitors and continue to be widely used to monitor daily ambulation activity, as a tool for prescribing increased mobility (eg, daily step targets) and motivating individuals to increase their activity level.13,14 However, the reduced measurement properties of pedometers in overweight/obese populations and among individuals with slower ambulation speeds continues to be a limitation.15,16

Although pedometers are a cost-effective tool, they are increasingly being replaced by accelerometers. Accelerometers offer the advantage of assessing all accelerative movements, in all directions, in addition to the ambulation data collected by a pedometer, and can be calibrated to detect differences in intensity.13 Data from accelerometers also allow for intervention content to be tailored.8 Until recently, research-grade activity monitors have not provided real-time feedback to patients due to a lack of a digital display, or required downloading and interpreting of data using specialized, costly analytic software. However, as the consumer market for wearable activity monitors has steadily grown, parallel shifts in the research market have also occurred, providing more options for personalized, real-time feedback. Activity monitors used by consumers and researchers now have extensive feedback programs that provide real-time data to the wearer via computer programs and mobile applications.17,18 Some of these devices even provide an option to relay this information to a third party such as family, friends, or clinicians. This ability to transmit data to patients' physicians and care teams makes these devices attractive for clinical applications, although this capability is in the early stages of implementation and evaluation.18

The Veterans Health Administration (VHA), the largest integrated healthcare system in the United States, recognizes the potential benefit of promoting the use of wearable activity monitors to increase physical activity among Veterans. Before care managers in the VHA embrace this technology and implement these tools in clinical care and wellness programs, the disease states affected, the types of devices studied, and the strategies most likely to affect physical activity outcomes need to be identified. The objective of this review is to synthesize the literature on newer wearable activity devices to determine effectiveness for physical activity outcomes and to describe factors that impact the effectiveness of wearable activity devices.