# ABBREVIATIONS TABLE

AHRQ: Agency for Healthcare Research and Quality
CCRBT: Cochrane Collaboration Risk of Bias Tool
CI: Confidence interval
COPD: Chronic obstructive pulmonary disease
ESP: Evidence-based Synthesis Program
GPS: Global positioning system
HSR&D: Health Services Research & Development
KQ: Key question
MD: Mean difference
MeSH: Medical Subject Heading
NCP: National Center for Health Promotion and Disease Prevention
PA: Physical activity
PICOTS: Population, intervention, comparator, outcome, timing, and setting
QUERI: Quality Enhancement Research Initiative
RCT: Randomized controlled trial
ROB: Risk of bias
SEM: Standard error of the mean
SMD: Standardized mean difference
SOE: Strength of evidence
VA: Veterans Affairs
VHA: Veterans Health Administration
VISN: Veterans Integrated Service Networks