# CHARACTERISTICS OF INCLUDED STUDIES

Study | Population N Randomized Device Name | Intervention | Comparator | Outcomes | Duration (Weeks) | Funding Source | Risk of Bias
Greene, 2013^1^ | Healthy volunteers 513 NR | 6 months access to online social network to post about weight and PA progress + continuous accelerometer use and feedback | Printed lifestyle guidelines on diet (sample daily meal plan with recommended serving sizes), recommendations on daily level of exercise, and articles on benefits of exercise and healthy eating | PA: Yes Weight: Yes Satisfaction: No | 12 to 24 | Industry | High
Koizumi, 2009^2^ | Older adults 68 Kenz Lifecorder accelerometer | 12 weeks of accelerometer with feedback + goal-setting | 12-week blinded accelerometer with instruction to continue normal daily activity | PA: Yes Weight: No Satisfaction: No | 12 to 24 | NR | High
Luley, 2014^3^ | Chronic medical illness 184 Aipermotion 440 accelerometer | 3-arm study (2 interventional): [underlined: 4s intervention:] 1-time, 2-hour instruction on diet & PA + 12 months of accelerometer use + 52 weekly individual letters with feedback on weight, diet, and PA [underlined: ABC intervention:] 1-time, 2-hour instruction on diet & PA + 12 months of accelerometer use + 12 monthly behavioral counseling calls | 1-time, 2-hour session, consisting of diet education, diet regimen, and PA education | PA: No Weight: Yes Satisfaction: No | 25+ | Gov | Unclear
Nicklas, 2014^4^ | Older adults 48 Lifecorder PlusVR tri-axial accelerometer | 5-month weight loss intervention that included hypocaloric diet (2 prepared meals a day) + 4 days/week supervised exercise + self-regulatory intervention that involved wearing an accelerometer, documenting activity, and 6 weekly sessions of behavioral counseling | 5-month weight loss intervention consisting of diet education and regimen (individualized hypocaloric intake), PA education, structured exercise (supervised treadmill) and in-person counseling | PA: Yes Weight: Yes Satisfaction: No | 25+ | Gov | High
Paschali, 2005^5^ | Chronic medical illness 30 BioTrainer accelerometer | 12 weeks of continuous accelerometer use and feedback + 4 monthly in-person exercise behavioral counseling sessions + workbook | 12-week blinded accelerometer with 4 monthly in-person counseling sessions to review exercise diary. A 24-page information book and home based walking plan with PA education, behavioral self-management, weight goal-setting, and chronic disease-monitoring. | PA: Yes Weight: No Satisfaction: No | 12 to 24 | Gov | High
Polzien, 2007^6^ | Overweight/obese and/or sedentary 57 SenseWear Pro Armband | 3-arm study: [underlined: Standard in-person behavioral weight control program:] 7 in-person individualized counseling session over 12 weeks [underlined: Continuous technology-based behavioral weight control program:] 7 in-person individualized counseling session over 12 weeks + 12 weeks of continuous accelerometer use and feedback [underlined: Intermittent technology-based behavioral weight control program:] 7 in-person individualized counseling session over 12 weeks + 3 weeks of accelerometer use and feedback over 12 weeks | 7 in-person individualized counseling sessions consisting of diet education, diet regimen (1200 to 1500 kcal/day; dietary fat <20% of total energy intake), PA education, and weight goal-setting | PA: Yes Weight: Yes Satisfaction: No | 12 to 24 | Industry | High
Reijonsaari, 2012^7^ | Healthy volunteers 544 Uni-axial accelerometer | 12 months of continuous accelerometer use and feedback + access to telephone counseling (frequency NR) | Written and verbal explanation of results of physical exams, general PA, and health information and occupational healthcare | PA: Yes Weight: Yes Satisfaction: No | 25+ | Fdn/Indiv | Low
Shrestha, 2013^8^ | Overweight/obese and/or sedentary 28 Polar FA20 accelerometer | 1-time, 1.5 hour lifestyle instruction + 6 months of continuous accelerometer use and feedback | Self-directed exercise and/or US Army mandated physical training | PA: Yes Weight: Yes Satisfaction: No | 12 to 24 | Gov | High
Shuger, 2011^9^ | Overweight/obese and/or sedentary 197 BodyMedia SenseWear Armband | 4-arm study (3 interventional arms) : [underlined: Group-based behavioral weight loss:] 14 group weight loss sessions + 6 individual phone calls + workbook over 9 months [underlined: Accelerometer alone:] 9 months of continuous accelerometer use and feedback [underlined: Group-based behavioral weight loss + accelerometer use:] 9 months of continuous accelerometer use and feedback + 14 group weight loss sessions + 6 individual phone calls + workbook | Self-directed weight loss manual with diet education, PA education, and weight goal-setting | PA: No Weight: Yes Satisfaction: No | 25+ | Industry | Unclear
Slootmaker, 2009^10^ | Overweight/obese and/or sedentary 102 PAM (model AM101), uniaxial activity monitor + smartphone | 3 months of continuous accelerometer use + tailored PA feedback and motivational tips via web-based portal | A single written brochure with brief PA recommendations | PA: Yes Weight: Yes Satisfaction: No | 12 to 24 | Gov | High
Tabak, 2014^11^ | Chronic medical illness 29 Activity Coach (accelerometer-based activity sensor + smartphone) | Self-directed technology supported care program that included a tailored web-based exercise program, accelerometer-based activity senor and motivational messaging, COPD self-management module, and as needed web-portal teleconsultation conducted over 9 months | Usual care with regular physiotherapy, if prescribed | PA: Yes Weight: No Satisfaction: No | 25+ | Gov | Unclear
Thompson, 2014^12^ | Overweight/obese and/or sedentary 20 GRUVE triaxial accelerometer | 12 weeks of continuous accelerometer use and feedback + weekly brief counseling sessions on increasing activity + treadmill desk | 12 weeks of monitoring without feedback, then crossed over to receive monitoring, plus feedback, counting, and treadmill desk for 12 weeks | PA: Yes Weight: Yes Satisfaction: No | 12 to 24 | Fdn | High
Thompson, 2014^13^ | Older adults 49 FitBit | 24 weeks of continuous accelerometer use and feedback + weekly brief telephone counseling sessions focused on accelerometer feedback + 6 in-person brief counseling sessions | 24 weeks of accelerometer without feedback | PA: Yes Weight: Yes Satisfaction: No | 25+ | Gov/Fdn | Unclear
Wijsman, 2013^14^ | Older adults 235 DirectLife | 12 weeks of continuous accelerometer use and feedback + personal website + personal e-coach who gives updates on activity status and advice via web portal | 3-month waitlist control | PA: Yes Weight: Yes Satisfaction: No | 12 to 24 | Gov/Industry | Low

Abbreviations: COPD=chronic obstructive pulmonary disease; Fdn=foundation; Gov=government; Indiv=individual; N=number; NR=not reported; PA=physical activity

## References in Appendix C

1 Greene J, Sacks R, Piniewski B, Kil D, Hahn JS. The impact of an online social network with wireless monitoring devices on physical activity and weight loss. J Prim Care Community Health. 2013;4(3):189-194. [pmid: 23799706].
2 Koizumi D, Rogers NL, Rogers ME, Islam MM, Kusunoki M, Takeshima N. Efficacy of an accelerometer-guided physical activity intervention in community-dwelling older women. J Phys Act Health. 2009;6(4):467-474. [pmid: 19842461].
3 Luley C, Blaik A, Gotz A, et al. Weight loss by telemonitoring of nutrition and physical activity in patients with metabolic syndrome for 1 year. J Am Coll Nutr. 2014;33(5):363-374. [pmid: 25105874].
4 Nicklas BJ, Gaukstern JE, Beavers KM, Newman JC, Leng X, Rejeski WJ. Self-monitoring of spontaneous physical activity and sedentary behavior to prevent weight regain in older adults. Obesity (Silver Spring). 2014;22(6):1406-1412. [pmid: 24585701].
5 Paschali AA, Goodrick GK, Kalantzi-Azizi A, Papadatou D, Balasubramanyam A. Accelerometer feedback to promote physical activity in adults with type 2 diabetes: a pilot study. Percept Mot Skills. 2005;100(1):61-68. [pmid: 15773694].
6 Polzien KM, Jakicic JM, Tate DF, Otto AD. The efficacy of a technology-based system in a short-term behavioral weight loss intervention. Obesity (Silver Spring). 2007;15(4):825-830. [pmid: 17426316].
7 Reijonsaari K, Vehtari A, Kahilakoski OP, van Mechelen W, Aro T, Taimela S. The effectiveness of physical activity monitoring and distance counseling in an occupational setting - results from a randomized controlled trial (CoAct). BMC Public Health. 2012;12:344. [pmid: 22578104].
8 Shrestha M, Combest T, Fonda SJ, Alfonso A, Guerrero A. Effect of an accelerometer on body weight and fitness in overweight and obese active duty soldiers. Mil Med. 2013;178(1):82-87. [pmid: 23356124].
9 Shuger SL, Barry VW, Sui X, et al. Electronic feedback in a diet- and physical activity-based lifestyle intervention for weight loss: a randomized controlled trial. Int J Behav Nutr Phys Act. 2011;8:41. [pmid: 21592351].
10 Slootmaker SM, Chinapaw MJ, Schuit AJ, Seidell JC, Van Mechelen W. Feasibility and effectiveness of online physical activity advice based on a personal activity monitor: randomized controlled trial. J Med Internet Res. 2009;11(3):e27. [pmid: 19674956].
11 Tabak M, Brusse-Keizer M, van der Valk P, Hermens H, Vollenbroek-Hutten M. A telehealth program for self-management of COPD exacerbations and promotion of an active lifestyle: a pilot randomized controlled trial. Int J Chron Obstruct Pulmon Dis. 2014;9:935-944. [pmid: 25246781].
12 Thompson WG, Koepp GA, Levine JA. Increasing physician activity with treadmill desks. Work. 2014;48(1):47-51. [pmid: 24004766].
13 Thompson WG, Kuhle CL, Koepp GA, McCrady-Spitzer SK, Levine JA. “Go4Life” exercise counseling, accelerometer feedback, and activity levels in older people. Arch Gerontol Geriatr. 2014;58(3):314-319. [pmid: 24485546].
14 Wijsman CA, Westendorp RG, Verhagen EA, et al. Effects of a web-based intervention on physical activity and metabolism in older adults: randomized controlled trial. J Med Internet Res. 2013;15(11):e233. [pmid: 24195965].