# PEER REVIEWER COMMENTS TABLE

Question Text | Reviewer Number | Comment | Response
Are the objectives, scope, and methods for this review clearly described? | 3 | Yes | N/A
Are the objectives, scope, and methods for this review clearly described?
Are the objectives, scope, and methods for this review clearly described? | 4 | Yes | N/A
Are the objectives, scope, and methods for this review clearly described?
Are the objectives, scope, and methods for this review clearly described? | 5 | Yes | N/A
Are the objectives, scope, and methods for this review clearly described?
Are the objectives, scope, and methods for this review clearly described? | 6 | No - My primary concern with this document is the broad conceptualization of the difference between an accelerometer and a pedometer. A pedometer is something that counts steps. An accelerometer is something that counts accelerations possibly with some additional metric of intensity. In the old days, pedometers counted steps using a spring and magnet internal mechanism. Now, most pedometers are actually using internal accelerometers to measure step counts. So, is a pedometer that uses an internal mechanism of an accelerometer a pedometer or an accelerometer. These are not technically mutually exclusive categories. Examples of accelerometer based pedometers include Stepwatch, Omron HJ-720 ITC and Fitbits. Many interventions using classic accelerometers such as actigraphs actually only feed back step count data even if they could feed back the full accelerometer data so would these count in this synthesis? It appears that you chose to exclude studies of interventions that use activity monitors with internal accelerometer mechanisms that report step counts back to the user rather than the full accelerometer data. The decision to exclude interventions that use accelerometer based activity trackers to give step count feedback over the internet seems arbitrary. Accelerometer based pedometers have all of the advantages of accelerometers except that they filter out non-step count accelerations before presenting the data (step count) to the wearer. If you want to do a synthesis of trials that feedback non-step count physical activity metrics obtained from an accelerometer, then the intro and justification needs to be rewritten to reflect this focus. As it is written, it does not currently make sense. It is simply not true that a) pedometers are less accurate than accelerometers (because many pedometers these days actually are accelerometers), b) accelerometers can link to electronic networks and devices but pedometers cannot (since the early days of the sportbrain, even spring and magnet pedometers have been able to upload step count data to networks and devices, now fitbits etc are accelerometer based pedometers that link up). I think you need to rewrite the criteria and clearly state that your question is - does feedback related to accelerometer count and intensity change physical activity, weight and other health outcomes. It is the data that is fed back to the user that varies - either step counts vs accelerations with intensity ratings. | Thank you for these comments. This report and other products have been explicitly developed to meet the needs of our stakeholder partners. There have been several excellent reviews of the effects of pedometers on physical activity and other health outcomes (Bravata, 2007, JAMA; Richardson, 2008, Annals of Family Medicine). As such, we developed a “white paper” that provides a review of recent good- and fair-quality systematic reviews on the effect of pedometer use on weight change, physical activity, and specific conditions of interest (eg, osteoarthritis, COPD, heart disease) to summarize the evidence for our primary stakeholders. Stakeholders were also interested in wearable technologies that measured activity beyond step counts (non-pedometer–based wearable motion sensing technologies), as those technologies tend to be more costly than traditional pedometers that only capture or report step counts. We agree that distinguishing between pedometers and accelerometers can be challenging. Our inclusion criteria consisted of the use of a wearable activity device that provided objective feedback to the wearer and was not defined as a pedometer-only device by study authors. To determine this, we used the author's definition of the device. If the underlying mechanics of a device were unclear, we searched online resources to determine each device type and manufacturer to ascertain if the predominate technology used something beyond, or in addition to, pedometers for step counts. We have added this information to Appendix C. All of the included wearable devices were considered to be accelerometers by manufacturer's definition. Our exclusion criteria did seek to exclude pedometer-based studies only if they identified themselves as a pedometer and feedback was not part of the intervention. We did not exclude studies where the intervention gave step count feedback over the internet. We did not restrict the type of feedback that was provided to the participant, and several articles included studies that measured physical activity on different scales and with different measures including step counts.
Are the objectives, scope, and methods for this review clearly described?
Are the objectives, scope, and methods for this review clearly described? | 7 | Yes | N/A
Is there any indication of bias in our synthesis of the evidence? | 3 | No | N/A
Is there any indication of bias in our synthesis of the evidence?
Is there any indication of bias in our synthesis of the evidence? | 4 | No | N/A
Is there any indication of bias in our synthesis of the evidence?
Is there any indication of bias in our synthesis of the evidence? | 5 | No | N/A
Is there any indication of bias in our synthesis of the evidence?
Is there any indication of bias in our synthesis of the evidence? | 6 | No | N/A
Is there any indication of bias in our synthesis of the evidence?
Is there any indication of bias in our synthesis of the evidence? | 7 | No | N/A
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | 3 | No | N/A
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked?
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | 4 | No | N/A
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked?
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | 5 | No | N/A
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked?
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | 6 | Yes - If you decide to include accelerometer based interventions that limit feedback to step count data then you have missed many studies. If the focus and exclusion criteria are really intended to exclude accelerometer based step count feedback interventions and if these criteria are made more coherent, then I think you may have all of the relevant studies. | Thank you for this comment. Our eligibility criteria did not exclude studies that limit feedback to step count data. We included any objective feedback that was provided to the participant (wearer) and that was not defined as a pedometer-only study by study authors.
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked?
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | 7 | No | N/A
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3 | Overall thorough and appears to be well-done. Key questions are addressed as well as can be for the amount of data available. | Thank you.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3 | 1) In the abstract, you report the SMD for the 9 studies using an inactive comparator for physical activity, and in the conclusions, you choose to highlight the SMD for the overall. I recommend being consistent in which estimate you highlight to avoid confusion. | 1) We agree about being consistent with the estimates we provide. We now provide inactive, active, and overall summary estimate for both outcomes.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3 | 2) In the abstract, you conclude that the devices produce small positive effects on physical activity and weight that are not likely to have a clinically significant impact on health outcomes. This statement strikes me as too definite of a conclusion. I think that your support for the small positive effects is well-substantiated in the methods, results, and conclusions. I think your support for the interpretation of the lack of clinically significant impact on health outcomes is lacking. If you wish to keep this statement in the conclusions of the abstract, you need to provide support in the Discussion for the fact that these small differences in physical activity and weight do not translate to differences in clinical outcomes (ok to make this judgment using data from other studies). If you don't provide adequate support for this statement, you may need to leave this more open-ended. Furthermore, the confidence intervals for effects are still relatively wide, and do not exclude a medium-sized effect. | 2) We agree that our conclusion was originally written too definitively. We have made changes to soften the conclusion and highlight the limitations in this body of literature. Specifically, we have indicated that the small positive effects found for these devices on physical activity and weight may not result in clinically important outcomes. We have also highlighted in the Abstract's conclusion that the small number of studies with small sample sizes and the moderate to high heterogeneity limit the conclusions that may be drawn.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3 | 3) On Forrest plots, it would be easier/faster to interpret if the subgroup “Summary” line was labeled (e.g. Inactive Comparator Summary, Active Comparator Summary). | 3) We have added labels to all the stratified summary estimates.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3 | 4) It wasn't a pre-defined KQ2 item, but it is mentioned a couple of times - would it be worth it to do a formal analysis on differences by duration of intervention? | 4) We did abstract the information on duration of intervention from individual studies. We did not, however, include intervention duration in the a priori analysis plan developed in collaboration with our primary stakeholders. As such, we report on those analyses that are a priori. We agree that formal analysis on differences by duration of intervention would be interesting, and we will explore including these in other analyses beyond this report.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3 | I think the section on Evidence Gaps and Future Research will end up being very helpful! | Thank you.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 4 | Overall, I commend the authors on an extremely well written synthesis of this literature. I was unable to locate any additional RCTs that would meet the search criteria. I believe this report to be unbiased and a fair assessment of or current knowledge of these technologies. I have made some minor comments below for clarification and consideration. | Thank you.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 4 | (p5, Abstract) – The abstract briefly mentions KQ2 in the background (i.e. factors affecting use), but nowhere else. The authors may consider adding a line about the paucity of literature in this regard should text limit be available. | We agree. We have added a sentence to the Results section that we did not identify any moderating factors that significantly impacted the effectiveness of the outcomes. This was our KQ 2 objective.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 4 | (pg5, Abstract) – In my opinion, the concluding statements could be revised somewhat to acknowledge the limitations of these data and relative immaturity of this field. | We agree. We have made changes to soften the conclusion and highlight the limitations in this body of literature.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 4 | (pg9, Introduction) – As the targeted audience for this report is VA clinicians, managers and policymakers – the authors may consider adding in some stats that are specific to Veterans and physical activity. For example, I believe there is some evidence that VA users in comparison to non-users are less likely to meet PA recommendations (Littman et al. 2009, MSSE). In addition, Consider including some relevant studies from VHA describing health-care costs and exercise capacity in Veterans (Weiss et al. 2004 Chest; Myers 2008 Curr Sports Med Report, etc.) including data derived from the Veterans Exercise Testing Study from Jon Myers' group in Palo Alto. | Thank you for the suggestion to more clearly highlight the relevance of this inactivity problem for our stakeholders and intended audience. We have expanded the Introduction to include specific statistics on Veterans and physical (in)activity as well as the healthcare cost implications of sedentary behavior/lifestyle, citing the compelling literature you provided.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 4 | (p61, Appendix B) – I'm not sure a column for risk of bias is necessary here as this was thoroughly covered in a prior section. | Thank you for this comment. We decided to add the risk of bias to the Appendix C table (formerly Appendix B table) since it was a standalone table and we felt that many readers may want to view the risk of bias assessment alongside the individual studies and study characteristics.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 5 | This report is a very elegant piece of work that clearly represents a tremendous amount of work undertaken to synthesize all of the available data on this topic. My concern is that the major take-home message of this report, from my perspective, may be a bit misleading which may to lead to erroneous assumptions about the outcomes. “We found that use of the wearable devices produces small positive effects that are not likely to have a clinically significant impact on health outcomes. Clinicians and policymakers should consider these findings before widespread use of this technology etc”. I believe some of the evidence gaps should be noted in the concluding statement. Policy makers might be inclined to conclude that there is no point in investing in this technology when in fact your data suggest that there is a paucity of well designed studies and that more research is needed that could better inform this decision. For example, on page 14 regarding KQa,the final sentence of the summary states that the “small number of studies, small sample sizes within these studies, and the moderate to high heterogeneity limits conclusions that may be drawn.” This statement sounds like a more overall accurate conclusion than what is currently stated on the abstract main conclusion which is what most people will be most likely to read. I also fear that it is a big jump to make a conclusion about clinical impact on health outcomes when the focus of this report is on behaviors (activity and weight management). | Thank you for your thorough and thoughtful review. We agree about the conclusions in the previous draft report. We have made changes to soften the conclusions and highlight the limitations in this body of literature. Specifically, we have indicated that the small positive effects found for these devices on physical activity and weight may not result in clinically important outcomes. We have also highlighted in the Abstract's conclusion that the small number of studies with small sample sizes and the moderate to high heterogeneity limit the conclusions that may be drawn.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 5 | On page 28 - Summary of findings. The last sentence is not clear. It has a double negative which I am not sure makes sense ‘The same trend was not seen for decreases in PA etc.” It seems that it should be “The same trend was not seen for greater increases in PA’ etc. | Thank you for identifying this error. We have changed to “greater increases in PA” as suggested.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 5 | On page 39 in the bottom paragraph of Clinical and Policy implications. This paragraph seems to be “promoting” use of devices and has some cautionary verbiage about the limitations of the evidence which seems to be contradictory to the conclusion in the structured abstract. It would seem to me that you can't have it both ways. These seem like mixed messages. I believe the data support this second conclusion more than the one in the structured abstract. | We agree. We have changed the structured Abstract as mentioned above to highlight the limitations in the body of literature.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 5 | The gaps and future research table is very useful. Hopefully this will guide future research. It was interesting to note the final row in which it was stated that no studies were recruited through clinical settings which should have a huge bearing on clinical policy makers in that we truly have no evidence in favor or against the use of wearable monitors in clinical settings. | Thank you.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 6 | 2) There are several intervention characteristics that we know have an impact on behavior change. Goal-setting is one that may be the most critical given the focus on self-monitoring. Others include strategies to overcome barriers, motivational interviewing etc. It would be helpful to understand if / how participants set or were prescribed activity count goals for each of the included studies. Did all the trials include some kind of coaching around goal setting. If not, does explicit attention to goal setting impact outcomes | 2) Thank you for posing this question. Due to the high heterogeneity in adjunctive interventions delivered alongside the activity devices, we were unable to explore these additions quantitatively. Table 3 outlines the types of adjunctive interventions used for each study. Thus, we chose to categorize the use of the activity device alongside the adjunct intervention as “major vs minor.” It would be interesting for future analyses to examine the impact on outcomes that goal-setting may have with these devices.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 6 | 3) The second question related to heterogeneity of treatment effect is so profoundly limited by small sample size that it probably should be reported as unable to judge due to risk of type 2 error rather than as not difference detected. | 3) We agree. We have highlighted in the report the small sample sizes found in individual trials. We added to the Limitations section that the small sample sizes found within this literature may have resulted in a type II error.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 6 | 4) Further limitations should be emphasized – there is insufficient evidence to determine if accelerometer based feedback is inferior, equivalent or superior to pedometer based feedback for any of the outcomes. | 4) Thank you for this suggestion. We have added this information to the Research Gaps/Future Research section of the report.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 7 | These comments are submitted on behalf of the National Center for Health Promotion and Disease Prevention (NCP). The report was thorough and organized and the information was presented in a clear manner. There were two points of potential clarification that we wanted to bring to the attention of the authors: 1. Pg. 1(lines 22-24)-physical activity diaries are included as a self-reported measure that “does little to motivate or change physical activity behavior…” While diaries and other real time records of self-monitored behavior are self-reported, they are not intended to be the same as questionnaires and interviews that gather self-reported data retrospectively. In addition, the act of attending to a target behavior using self-monitoring strategies has been shown to result in behavior change. Unless there is evidence to suggest that self-monitoring of behavior IS NOT associated with behavior change, or self-monitoring of physical activity is NOT associated with changes in physical activity, it may be helpful to reword this sentence. | Thank you for the positive comments about the thoroughness and organization of the report. 1) We agree with the review team that the way the sentence on page1, lines 22-24, is written is misleading. We initially intended to indicate that these self-report measures, such as diaries, may not be an optimal measurement strategy rather than imply them as intervention strategies. We have since revised the report to read, “Physical activity has previously been measured using self-reported measures (eg, questionnaires, interviews.); however, these do little to motivate or change physical activity behavior and can be subject to reporting bias.”
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 7 | 2. Pg. 16 (lines 33-54), Figure 4 - What does the absence of color/white colored bar represent? Also, it appears that the overall percentage of high risk of bias (as indicated by the proportion of the bar colored red in the “Overall” row) is much larger than one would expect given the relatively low risk of bias (as depicted by minimal red coloring in each of the individual risk of bias items). Additional description of the information in Figure 4 may provide clarity on these issues. | 2) Thank you for noticing this error. We have revised the Risk of Bias figure and removed the “clear” space from the PA and weight questions. This occurred since overall we had 14 studies included; however, some studies did not include both outcomes of interest. There is high risk of bias in many of the studies even without individual questions being rated as high risk because of the way the overall evaluation is calculated. In the Methods section, we describe the scoring process for “high risk” which includes two or more domain questions that are “not clear.” As such, many of the studies had “not clear” domain questions, leading to an overall high risk of bias. We have added the scoring as a footnote to Figure 4.