# SEARCH STRATEGIES

## Database: MEDLINE (via PubMed)

### Search date: 01/06/15

Set # | Search Terms | Results
#1 | “Accelerometry”[Mesh] OR “Magnetometry”[Mesh] OR “Motor Activity/instrumentation”[Mesh] OR fitness track*[tiab] OR activity track*[tiab] OR fitness monitor*[tiab] OR gps[tiab] OR “global positioning”[tiab] OR activity monitor*[tiab] OR motion sens*[tiab] OR accelerometer[tiab] OR accelerometers[tiab] OR accelerometry[tiab] OR gyroscope[tiab] OR gyroscopic[tiab] OR gyroscopes[tiab] OR actograph[tiab] OR actographic[tiab] OR actography[tiab] OR actographs[tiab] OR wearable system[tiab] OR wearable systems[tiab] OR wearable sensor[tiab] OR wearable sensors[tiab] OR ((step[tiab] OR steps[tiab]) AND (counting[tiab] OR counted[tiab] OR counter[tiab] OR counters[tiab] OR count[tiab])) OR actigraph[tiab] OR (basis[tiab] AND peak[tiab]) OR “bowflex boost”[tiab] OR “fit link”[tiab] OR (misfit[tiab] AND shine[tiab]) OR (polar[tiab] AND loop[tiab]) OR bodybugg[tiab] OR bodymedia[tiab] OR fitbit[tiab] OR fitbug[tiab] OR fuelband[tiab] OR garmin[tiab] OR gowear[tiab] OR gruve[tiab] OR ibitz[tiab] OR iqua[tiab] OR lumo[tiab] OR motoactiv[tiab] OR runtastic[tiab] OR scosche[tiab] OR smartband[tiab] OR striiv[tiab] OR tomtom[tiab] OR vivofit[tiab] OR vivosmart[tiab] OR wahoo[tiab] OR wakemate[tiab] OR withings[tiab] | 52,751
#2 | “Movement”[Mesh] OR “Exercise Movement Techniques”[Mesh] OR “Exercise Therapy”[Mesh] OR “Physical Fitness”[Mesh] OR “Physical Endurance”[Mesh] OR “Physical Exertion”[Mesh] OR fitness[tiab] OR activity[tiab] OR active[tiab] OR walk*[tiab] OR run*[tiab] OR step[tiab] OR steps[tiab] OR exercise[tiab] OR move*[tiab] | 3,555,057
#3 | (randomized controlled trial[pt] OR controlled clinical trial[pt] OR randomized[tiab] OR randomised[tiab] OR randomization[tiab] OR randomisation[tiab] OR randomly[tiab] OR trial[tiab] OR groups[tiab]) NOT (Editorial[ptyp] OR Letter[ptyp] OR Case Reports[ptyp] OR Comment[ptyp]) | 2,079,904
#4 | #1 AND #2 AND #3 | 4858
#5 | #4 NOT (“Child”[Mesh] NOT “Adult”[Mesh]) | 4355
#6 | #5, English, 2000 - present | 3506

## Database: Embase

### Search date: 01/06/15

Set # | Search Terms | Results
#1 | ‘accelerometry’/exp OR ‘magnetometry’/exp OR (fitness NEAR/2 track*):ab,ti OR (activity NEAR/2 track*):ab,ti OR (fitness NEAR/2 monitor*):ab,ti OR gps:ab,ti OR ‘global positioning’:ab,ti OR (activity NEAR/2 monitor):ab,ti OR (motion NEAR/2 sens*):ab,ti OR accelerometer:ab,ti OR accelerometers:ab,ti OR accelerometry:ab,ti OR gyroscope:ab,ti OR gyroscopic:ab,ti OR gyroscopes:ab,ti OR actograph:ab,ti OR actographic:ab,ti OR actography:ab,ti OR actographs:ab,ti OR ‘wearable system’:ab,ti OR ‘wearable systems’:ab,ti OR ‘wearable sensor’:ab,ti OR ‘wearable sensors’:ab,ti OR ((step OR steps):ab,ti AND (counting OR counted OR counter OR counters OR count):ab,ti) OR actigraph:ab,ti OR (basis NEAR/3 peak):ab,ti,df OR ‘bowflex boost’:ab,ti,df OR ‘fit link’:ab,ti,df OR (misfit NEAR/3 shine):ab,ti,df OR (polar NEAR/3 loop):ab,ti,df OR bodybugg:ab,ti,df OR bodymedia:ab,ti,df OR fitbit:ab,ti,df OR fitbug:ab,ti,df OR fuelband:ab,ti,df OR garmin:ab,ti,df OR gowear:ab,ti,df OR gruve:ab,ti,df OR ibitz:ab,ti,df OR iqua:ab,ti,df OR lumo:ab,ti,df OR motoactiv:ab,ti,df OR runtastic:ab,ti,df OR scosche:ab,ti,df OR smartband:ab,ti,df OR striiv:ab,ti,df OR tomtom:ab,ti,df OR vivofit:ab,ti,df OR vivosmart:ab,ti,df OR wahoo:ab,ti,df OR wakemate:ab,ti,df OR withings:ab,ti,df | 45,316
#2 | ‘movement (physiology)’/exp OR ‘physical activity, capacity and performance’/exp OR ‘kinesiotherapy’/exp OR ‘fitness’/exp OR fitness:ab,ti OR activity:ab,ti OR active:ab,ti OR walk*:ab,ti OR run*:ab,ti OR step:ab,ti OR steps:ab,ti OR exercise:ab,ti OR move*:ab,ti | 4,564,954
#3 | (‘randomized controlled trial’/exp OR ‘crossover procedure’/exp OR ‘double blind procedure’/exp OR ‘single blind procedure’/exp OR random*:ab,ti OR factorial*:ab,ti OR crossover*:ab,ti OR (cross NEAR/1 over*):ab,ti OR (doubl* NEAR/1 blind*):ab,ti OR (singl* NEAR/1 blind*):ab,ti OR assign*:ab,ti OR allocat*:ab,ti OR volunteer*:ab,ti) NOT (‘case report’/exp OR ‘case study’/exp OR ‘editorial’/exp OR ‘letter’/exp OR ‘note’/exp) | 1,431,100
#4 | #1 AND #2 AND #3 | 3250
#5 | #4 NOT (‘child’/exp NOT ‘adult’/exp) | 2888
#6 | #5 AND [embase]/lim NOT [medline]/lim | 1051
#7 | #6, Limits: English, 2000- | 988

## Database: CINAHL

### Search date: 01/06/15

Set # | Search Terms | Results
#1 | (MH “Accelerometry”) OR (MH “Magnetics+”) OR TI (“fitness track*” or “activity track*” or “fitness monitor*” or gps or “global positioning” or “activity monitor*” or “motion sens*” or accelerometer or accelerometers or accelerometry or gyroscope or gyroscopic or gyroscopes or actograph or actographic or actography or actographs or “wearable system” or “wearable systems” or “wearable sensor” or “wearable sensors” or ((step or steps) and (counting or counted or counter or counters or count)) or actigraph or (basis and peak) or “bowflex boost” or “fit link” or (misfit and shine) or (polar and loop) or bodybugg or bodymedia or fitbit or fitbug or fuelband or garmin or gowear or gruve or ibitz or iqua or lumo or motoactiv or runtastic or scosche or smartband or striiv or tomtom or vivofit or vivosmart or wahoo or wakemate or withings) OR AB (“fitness track*” or “activity track*” or “fitness monitor*” or gps or “global positioning” or “activity monitor*” or “motion sens*” or accelerometer or accelerometers or accelerometry or gyroscope or gyroscopic or gyroscopes or actograph or actographic or actography or actographs or “wearable system” or “wearable systems” or “wearable sensor” or “wearable sensors” or ((step or steps) and (counting or counted or counter or counters or count)) or actigraph or (basis and peak) or “bowflex boost” or “fit link” or (misfit and shine) or (polar and loop) or bodybugg or bodymedia or fitbit or fitbug or fuelband or garmin or gowear or gruve or ibitz or iqua or lumo or motoactiv or runtastic or scosche or smartband or striiv or tomtom or vivofit or vivosmart or wahoo or wakemate or withings) | 14,089
#2 | (MH “Movement+”) OR (MH “Exercise+”) OR (MH “Therapeutic Exercise+”) OR (MH “Physical Activity”) OR (MH “Physical Fitness+”) OR (MH “Exertion+”) OR TI (OR fitness OR activity OR active OR walk* OR run* OR step OR steps OR exercise OR move*) OR AB (OR fitness OR activity OR active OR walk* OR run* OR step OR steps OR exercise OR move*) | 361,653
#3 | (MH “Treatment Outcomes+”) OR randomized OR PT clinical trial | 317,587
#4 | #1 AND #2 AND #3 | 636
#5 | #4, English, 2000- | 602

## Database: SPORTDiscus

### Search date: 01/06/15

Set # | Search Terms | Results
#1 | DE “ACCELEROMETERS” OR TI (“fitness track*” or “activity track*” or “fitness monitor*” or gps or “global positioning” or “activity monitor*” or “motion sens*” or accelerometer or accelerometers or accelerometry or gyroscope or gyroscopic or gyroscopes or actograph or actographic or actography or actographs or “wearable system” or “wearable systems” or “wearable sensor” or “wearable sensors” or ((step or steps) and (counting or counted or counter or counters or count)) or actigraph or (basis and peak) or “bowflex boost” or “fit link” or (misfit and shine) or (polar and loop) or bodybugg or bodymedia or fitbit or fitbug or fuelband or garmin or gowear or gruve or ibitz or iqua or lumo or motoactiv or runtastic or scosche or smartband or striiv or tomtom or vivofit or vivosmart or wahoo or wakemate or withings) OR AB (“fitness track*” or “activity track*” or “fitness monitor*” or gps or “global positioning” or “activity monitor*” or “motion sens*” or accelerometer or accelerometers or accelerometry or gyroscope or gyroscopic or gyroscopes or actograph or actographic or actography or actographs or “wearable system” or “wearable systems” or “wearable sensor” or “wearable sensors” or ((step or steps) and (counting or counted or counter or counters or count)) or actigraph or (basis and peak) or “bowflex boost” or “fit link” or (misfit and shine) or (polar and loop) or bodybugg or bodymedia or fitbit or fitbug or fuelband or garmin or gowear or gruve or ibitz or iqua or lumo or motoactiv or runtastic or scosche or smartband or striiv or tomtom or vivofit or vivosmart or wahoo or wakemate or withings) | 6204
#2 | (random* OR trial) | 56299
#3 | #1 AND #2 | 639
#4 | #3, English, 2000-, Academic Journals | 543

## Database: Cochrane CENTRAL

### Search date: 01/06/15

Set # | Search Terms | Results
#1 | [mh Accelerometry] OR [mh Magnetometry] | 341
#2 | “fitness track*”:ab,ti or “activity track*”:ab,ti or “fitness monitor*”:ab,ti or gps:ab,ti or “global positioning”:ab,ti or “activity monitor*”:ab,ti or “motion sens*”:ab,ti or accelerometer:ab,ti or accelerometers:ab,ti or accelerometry:ab,ti or gyroscope:ab,ti or gyroscopic:ab,ti or gyroscopes:ab,ti or actograph:ab,ti or actographic:ab,ti or actography:ab,ti or actographs:ab,ti or “wearable system”:ab,ti or “wearable systems”:ab,ti or “wearable sensor”:ab,ti or “wearable sensors”:ab,ti or ((step:ab,ti or steps:ab,ti) and (counting:ab,ti or counted:ab,ti or counter:ab,ti or counters:ab,ti or count:ab,ti)) or actigraph:ab,ti or (basis:ab,ti and peak:ab,ti) or “bowflex boost”:ab,ti or “fit link”:ab,ti or (misfit:ab,ti and shine:ab,ti) or (polar:ab,ti and loop:ab,ti) or bodybugg:ab,ti or bodymedia:ab,ti or fitbit:ab,ti or fitbug:ab,ti or fuelband:ab,ti or garmin:ab,ti or gowear:ab,ti or gruve:ab,ti or ibitz:ab,ti or iqua:ab,ti or lumo:ab,ti or motoactiv:ab,ti or runtastic:ab,ti or scosche:ab,ti or smartband:ab,ti or striiv:ab,ti or tomtom:ab,ti or vivofit:ab,ti or vivosmart:ab,ti or wahoo:ab,ti or wakemate:ab,ti or withings:ab,ti | 2945
#3 | #1 OR #2 | 3204
#4 | [mh “Movement”] OR [mh “Exercise Movement Techniques”] OR [mh “Exercise Therapy”] OR [mh “Physical Fitness”] OR [mh “Physical Endurance”] OR [mh “Physical Exertion”] | 29,268
#5 | fitness:ab,ti OR activity:ab,ti OR active:ab,ti OR walk*:ab,ti OR run*:ab,ti OR step:ab,ti OR steps:ab,ti OR exercise:ab,ti OR move*:ab,ti | 134,034
#6 | #4 OR #5 | 140,071
#7 | #3 AND #6 | 1630
#6 | #5, 2000 – present, In Trials | 1281