# REFERENCES

1 Jimison H, Gorman P, Woods S, et al. Barriers and Drivers of Health Information Technology Use for the Elderly, Chronically Ill, and Underserved. AHRQ Publication No. 09-E004. 2008. Evidence Report/Technology Assessment No. 175.
2 Gibbons MC, Wilson RF, Samal L, et al. Impact of Consumer Health Informatics Applications. Agency for Healthcare Research and Quality. Evidence Report/Technology Assessment No. 188. 2009. AHRQ Publication No. 09(10)-E019.
3 Nielsen J. Designing Web Usability: The Practice of Simplicity. Indianapolis. New Riders Publishing. 1999.
4 Brennan PF, Downs SM, Casper G. Project Health Design: Rethinking the power and potential of personal health records. Journal of Biomedical Informatics. 2010;43(5 Suppl):S3-5. [pmid: 20937482].
5 Houser A, Gibson MJ. Valuing the Invaluable: The Economic Value of Family Caregiving, 2008 Update. AARP Public Policy Institute, From Insight on the Issues 13, November, 2008. http://www.aarp.org/ppi. accessed 6/11/2012.
6 Fox S. Health Topics. Report of the Pew Internet & American Life Project. Feb. 1. 2011. http://pewinternet.org/Reports/2011/HealthTopics.aspx. Accessed 6/11/2012.
7 Fox S, Jones S. The Social Life of Health Information. Report of the Pew Internet & American Life Project. May. 12. 2011. http://pewinternet.org/Reports/2011/Social-Life-of-Health-Info.aspex. accessed 6/11/2012.
8 Zickuhr K, Smith A. Digital differences. Report of the Pew Research Center’s Internet & American Life Project. April. 13. 2012.
9 McInnes DK, Gifford AL, Kazis LE, Wagner TH. Disparities in health-related internet use by US veterans: results from a national survey. Informatics in Primary Care. 2010;18(1):59-68.
10 Consumer Health Informatics Taxonomy Delphi Study at Saint Louis University. https://slu.qualtrics.com/SE/?SID=SV_bqq7PCrC1Vo96GE. Accessed on 6/13. 2012. Accessed 6/13/2012.
11 Ahern DK, Woods SS, Lightowler MC, Finley SW, Houston TK. Promise of and Potential for Patient-Facing Technologies to Enable Meaningful Use. Am J Prev Med. 2011;40(5S2):S162-S172. [pmid: 21521591].
12 Best Care Together: Meeting Veterans Needs with Health Information Technology. 2011.
13 Craig P, Dieppe P, MacIntyre S, Michie S, Nazareth I, Petticrew M. Developing and evaluating complex interventions: new guidance. Medical Research Council (MRC). Accessed June 7, 2012. http://www.mrc.ac.uk/complexinterventionsguidance. 2008.
14 Vehvilainen L, Zielstorff R, Gertman P, Tzeng M, Estey G. Alzheimer’s Caregiver Internet Support System (ACISS): Evaluating the Feasibility and Effectiveness of Supporting Family Caregivers Virtually. Paper presented at: AMIA Annual Symposium Proceedings. 2002.
15 Becker SA, Webbe F. Use of Handheld Technology by Older Adult Caregivers as Part of a Virtual Support Network. Paper presented at: Pervasive Health Conference and Workshops, 2006. Nov.–Dec. 2006. 2006.
16 Beauchamp N, Irvine AB, Seeley J, Johnson B. Worksite-based internet multimedia program for family caregivers of persons with dementia. Gerontologist. Dec. 2005;45(6):793-801. [pmid: 16326661].
17 Chiu T, Lottridge D. Development and iterative refinement of an internet-based service for Chinese family caregivers of people with Alzheimer Disease. AMIA Annu Symp Proc. 2005;919.
18 Chiu T, Marziali E, Colantonio A, et al. Internet-based caregiver support for Chinese Canadians taking care of a family member with alzheimer disease and related dementia. Can J Aging. Dec. 2009;28(4):323-336. [pmid: 19925698].
19 Bass DM, McClendon MJ, Brennan PF, McCarthy C. The buffering effect of a computer support network on caregiver strain. Journal of Aging & Health. Feb. 1998;10(1):20-43. [pmid: 10182416].
20 Brennan PF, Moore SM, Smyth KA. The effects of a special computer network on caregivers of persons with Alzheimer’s disease. Nursing research. May–Jun. 1995;44(3):166-172. [pmid: 7761293].
21 Kuwahara N, Kuwabara K, Utsumi A, Yasuda K, Tetsutani N. Networked interaction therapy: relieving stress in memory-impaired people and their family members. Conf Proc IEEE Eng Med Biol Soc. 2004;5:3140-3143. [pmid: 17270945].
22 Hill-Kayser CE, Vachani C, Hampshire MK, Jacobs LA, Metz JM. An internet tool for creation of cancer survivorship care plans for survivors and health care providers: design, implementation, use and user satisfaction. J Med Internet Res. 2009;11(3):e39. [pmid: 19734128].
23 Namkoong K, Dubenske LL, Shaw BR, et al. Creating a Bond Between Caregivers Online: Effect on Caregivers’ Coping Strategies. J Health Commun. Oct. 17. 2011.
24 Nolan MT, Hodgin MB, Olsen SJ, et al. Spiritual issues of family members in a pancreatic cancer chat room. Oncol Nurs Forum. Mar. 2006;33(2):239-244. [pmid: 16518439].
25 Diefenbach MA, Butz BP. A multimedia interactive education system for prostate cancer patients: development and preliminary evaluation. J Med Internet Res. Jan. 21. 2004;6(1):e3. [pmid: 15111269].
26 Pierce LL, Steiner VL, Khuder SA, Govoni AL, Horn LJ. The effect of a Web-based stroke intervention on carers’ well-being and survivors’ use of healthcare services. Disabil Rehabil. 2009;31(20):1676-1684. [pmid: 19479528].
27 Steiner V, Pierce L, Drahuschak S, Nofziger E, Buchman D, Szirony T. Emotional support, physical help, and health of caregivers of stroke survivors. J Neurosci Nurs. Feb. 2008;40(1):48-54. [pmid: 18330410].
28 Keaton L, Pierce LL, Steiner V, et al. An E-rehabilitation Team Helps Caregivers Deal with Stroke. The Internet Journal of Allied Health Sciences and Practice. 2004;2(4).
29 Pierce LL, Steiner V, Govoni AL, Hicks B, Cervantez Thompson TL, Friedemann ML. Internet-based support for rural caregivers of persons with stroke shows promise. Rehabil Nurs. 2004/05/22. 2004;29:95-99. 103. [pmid: 15152419].
30 Pierce LL, Steiner V, Govoni AL, Hicks B, Cervantez Thompson TL, Friedemann M. Caregivers Dealing with Stroke Pull together and Feel Connected. Journal of Neuroscience Nursing. 2004;36(a).
31 Pierce LL, Steiner V, Govoni AL. In-home online support for caregivers of survivors of stroke: a feasibility study. Comput Inform Nurs. Jul–Aug. 2002;20(4):157-164. [pmid: 12105404].
32 Stjernsward S, Ostman M. Illuminating user experience of a website for the relatives of persons with depression. Int J Soc Psychiatry. Jul. 2011;57(4):375-386. [pmid: 20233895].
33 Glynn SM, Randolph ET, Garrick T, Lui A. A proof of concept trial of an online psychoeducational program for relatives of both veterans and civilians living with schizophrenia. Psychiatr Rehabil J. Spring. 2010;33(4):278-287. [pmid: 20374986].
34 Rotondi AJ, Sinkule J, Spring M. An interactive Web-based intervention for persons with TBI and their families: use and evaluation by female significant others. J Head Trauma Rehabil. Mar–Apr. 2005;20(2):173-185. [pmid: 15803040].
35 Rotondi AJ, Haas GL, Anderson CM, et al. A clinical trial to test the feasibility of a telehealth psychoeducational intervention for persons with schizophrenia and their families: intervention and 3-month findings. Rehabilitation Psychology. 2005;50(4):325-336. [pmid: 26321774].
36 Chiu T, Massimi M. A Digital Support Device Designed to Help Family Caregivers Coordinate, Communicate and Plan the Care of People with Brain Injury. AMIA Symposium Proceedings. 2006;884.
37 Huang F, Liu SC, Shih SM, et al. Reducing the anxiety of surgical patient’s families access short message service. AMIA Annu Symp Proc. 2006;957.
38 Dew MA, Goycoolea JM, Harris RC, et al. An internet-based intervention to improve psychosocial outcomes in heart transplant recipients and family caregivers: development and evaluation. J Heart Lung Transplant. Jun. 2004;23(6):745-758. [pmid: 15366436].
39 Chambers M, Connor SL. User-friendly technology to help family carers cope. J Adv Nurs. Dec. 2002;40(5):568-577. [pmid: 12437606].
40 Magnusson L, Hanson E. Supporting frail older people and their family carers at home using information and communication technology: cost analysis. J Adv Nurs. Sep. 2005;51(6):645-657. [pmid: 16129015].
41 Magnusson L. The impact of information and communication technology on family carers of older people and professionals in Sweden. Ageing and Society. 2005;(25).
42 Finn J. An exploration of helping processes in an online self-help group focusing on issues of disability. Health Soc Work. 1999;24.
43 Fitzgerald SA, Macan Yadrich D, Werkowitch M, Piamjariyakul U, Smith CE. Creating patient and family education web sites: design and content of the home parenteral nutrition family caregivers web site. Comput Inform Nurs. Nov. 2011;29(11):637-645. [pmid: 21825970].
44 Ossebaard HC, van Gemert-Pijnen JE, Sorbi MJ, Seydel ER. A study of a Dutch online decision aid for parents of children with ADHD. J Telemed Telecare. 2010;16(1):15-19. [pmid: 20086262].
45 Stinson J, McGrath P, Hodnett E, et al. Usability testing of an online self-management program for adolescents with juvenile idiopathic arthritis. J Med Internet Res. 2010;12(3):e30. [pmid: 20675293].
46 Krishna S, Francisco B, Boren SA, Balas EA. Evaluation of a Web-based Interactive Multimedia Pediatric Asthma Education Program. Paper presented at: AMIA Symposium Proceedings. 2000.
47 Krishna S, Francisco BD, Balas EA, et al. Internet-enabled interactive multimedia asthma education program: a randomized trial. Pediatrics. Mar. 2003;111(3):503-510. [pmid: 12612228].
48 Bergmo TS, Wangberg SC, Schopf TR, Solvoll T. Web-based consultations for parents of children with atopic dermatitis: results of a randomized controlled trial. Acta Paediatr. Feb. 2009;98(2):316-320. [pmid: 18795905].
49 Askins MA, Sahler OJ, Sherman SA, et al. Report from a multi-institutional randomized clinical trial examining computer-assisted problem-solving skills training for English- and Spanish-speaking mothers of children with newly diagnosed cancer. J Pediatr Psychol. Jun. 2009;34(5):551-563. [pmid: 19091804].
50 Ewing LJ, Long K, Rotondi A, Howe C, Bill L, Marsland AL. Brief report: A pilot study of a web-based resource for families of children with cancer. J Pediatr Psychol. Jun. 2009;34(5):523-529. [pmid: 18784185].
51 Han HR, Belcher AE. Computer-mediated support group use among parents of children with cancer--an exploratory study. Comput Nurs. Jan–Feb. 2001;19(1):27-33. [pmid: 11210451].
52 Lewis D, Cooper J, Gunawardena S. Caring Connection: Internet resources for family caregivers of children with cancer. AMIA Annu Symp Proc. 2006:1007. [pmid: 17238626].
53 Gulmans J, Vollenbroek-Hutten MM, Visser JJ, Nijeweme-d’Hollosy WO, van Gemert-Pijnen JE, van Harten WH. A web-based communication system for integrated care in cerebral palsy: design features, technical feasibility and usability. J Telemed Telecare. 2010;16(7):389-393. [pmid: 20736247].
54 Britto MT, Jimison HB, Munafo JK, Wissman J, Rogers ML, Hersh W. Usability testing finds problems for novice users of pediatric portals. J Am Med Inform Assoc. Sep–Oct. 2009;16(5):660-669. [pmid: 19567793].
55 Nelson TM, Berg JH, Bell JF, Leggott PJ, Seminario AL. Assessing the effectiveness of text messages as appointment reminders in a pediatric dental setting. J Am Dent Assoc. Apr. 2011;142(4):397-405. [pmid: 21454845].
56 Demaso DR, Marcus NE, Kinnamon C, Gonzalez-Heydrich J. Depression experience journal: a computer-based intervention for families facing childhood depression. J Am Acad Child Adolesc Psychiatry. Feb. 2006;45(2):158-165. [pmid: 16429086].
57 Keshavjee K, Lawson ML, Malloy M, Hubbard S, Grass M. Technology failure analysis: understanding why a diabetes management tool developed for a Personal Digital Assistant (PDA) didn’t work in a randomized controlled trial. AMIA Annu Symp Proc. 2003;889.
58 Nordfeldt S, Hanberger L, Bertero C. Patient and parent views on a Web 2.0 Diabetes Portal--the management tool, the generator, and the gatekeeper: qualitative study. J Med Internet Res. 2010;12(2):e17. [pmid: 20511179].
59 Stockwell MS, Kharbanda EO, Martinez RA, et al. Effect of a text messaging intervention on influenza vaccination in an urban, low-income pediatric and adolescent population: a randomized controlled trial. JAMA. April. 25. 2012;307(16):1702-1708. [pmid: 22535855].
60 Miloh T, Annunziato R, Arnon R, et al. Improved adherence and outcomes for pediatric liver transplant recipients by using text messaging. Pediatrics. Nov. 2009;124(5):e844-850. [pmid: 19822583].
61 Safran C, Pompilio-Weitzner G, Emery KD, Hampers L. A Medicaid eHealth program: an analysis of benefits to users and nonusers. AMIA Annu Symp Proc. 2005:659-663. [pmid: 16779122].
62 Goldman RD, Antoon R, Tait G, Zimmer D, Viegas A, Mounstephen B. Culture results via the internet: a novel way for communication after an emergency department visit. J Pediatr. Aug. 2005;147(2):221-226. [pmid: 16126054].
63 Mindell JA, Du Mond CE, Sadeh A, Telofski LS, Kulkarni N, Gunn E. Efficacy of an internet-based intervention for infant and toddler sleep disturbances. Sleep. Apr. 2011;34(4):451-458. [pmid: 21461323].
64 Wade SL, Carey J, Wolfe CR. An online family intervention to reduce parental distress following pediatric brain injury. J Consult Clin Psychol. Jun. 2006;74(3):445-454. [pmid: 16822102].
65 Carey JC, Wade SL, Wolfe CR. Lessons learned: the effect of prior technology use on Web-based interventions. Cyberpsychol Behav. Apr. 2008;11(2):188-195. [pmid: 18422412].
66 Wade SL, Wolfe CR, Pestian JP. A web-based family problem-solving intervention for families of children with traumatic brain injury. Behav Res Methods Instrum Comput. May. 2004;36(2):261-269. [pmid: 15354692].
67 Wade SL, Walz NC, Carey JC, Williams KM. Preliminary efficacy of a Web-based family problem-solving treatment program for adolescents with traumatic brain injury. J Head Trauma Rehabil. Nov–Dec. 2008;23(6):369-377. [pmid: 19033829].
68 Wade SL, Walz NC, Carey JC, Williams KM. Brief report: Description of feasibility and satisfaction findings from an innovative online family problem-solving intervention for adolescents following traumatic brain injury. J Pediatr Psychol. Jun. 2009;34(5):517-522. [pmid: 18667477].
69 Marsac ML, Kassam-Adams N, Hildenbrand AK, Kohser KL, Winston FK. After the injury: initial evaluation of a web-based intervention for parents of injured children. Health Educ Res. Feb. 2011;26(1):1-12. [pmid: 20858769].
70 Impact of a Patient Portal to Improve Quality of Care in an Autism Clinic. 2011.
71 Glueckauf RL, Ketterson TU, Loomis JS, Dages P. Online support and education for dementia caregivers: overview, utilization, and initial program evaluation. Telemed J E Health. Summer. 2004;10(2):223-232. [pmid: 15319052].
72 Becker SA, Webbe F. The Potential of Hand-held Assistive Technology to Improve Safety for Elder Adults Aging in Place. Henriksen K, Battles JB, Keyes MA, Lewin DI, editors. Advances in Patient Safety: New Directions and Alternative Approaches. Bethesda, MD. Agency for Healthcare Research and Quality (AHRQ). 2008:107-119.
73 Magnusson L. A literature review study of Information and Communication Technology as a support for frail older people living at home and their family carers. Technology and Disability. 2004;16:223-235. 214. 221. 213.
74 Magnusson L, Hanson E. Support “online” for older people and their family carers -- the EU project ACTION... Assisting Carers using Telematics Interventions to meet Older person’s Needs. Geneva, Switzerland. International Council of Nurses. 2001.
75 Usability Professionals’ Association. What is user-centered design?. http://www.usabilityprofessionals.org/usability_resources/about_usability/what_is_ucd.html. accessed June 14, 2012.
76 Smith A. 17% of cell phone owners do most of their online browsing on their phone, rather than a computer or other device. Pew Research Center’s Internet & American Life Project. 2012. http://pewinternet.org/Reports/2012/Cell-Internet-Use-2012.aspx.
77 U.S. Department of Health & Human Services. Usability.gov - Your guide for developing usable & useful Web sites. http://www.usability.gov/. Accessed October 25, 2012.
78 McLean S, Chandler D, Nurmatov U, et al. Telehealthcare for Asthma: A Cochrane Review. CMAJ. 2011;183(11):E733-742. [pmid: 21746825].
79 McLean S, Nurmatov U, Liu JL, Pagliari C, Car J, Sheikh A. Telehealthcare for Chronic Obstructive Pulmonary Disease. Cochrane Database of Systematic Reviews. 2011;(7).
80 Farmer A, Gibson OJ, Tarassenko L, Neil A. A Systematic Review of Telemedicine Interventions to Support Blood Glucose Self-monitoring in Diabetes. Diabet Med. 2005;22(10):1372-1378. [pmid: 16176199].
81 Hersh WR, Hickam DH, Severance SM, Dana TL, Krages KP, Helfand M. Telemedicine for the Medicare Population: Update. Evid Rep Technol Assess (Full Rep). 2006;(131):1-41. [pmid: 17900201].
82 Greist JH, Osgood-Hynes DJ, Baer L, Marks IM. Technology-Based Advances in the Management of Depression: Focus on the COPE(TM) Program. Disease Management & Health Outcomes. 2000;7(4):193-200. 198.
83 McDaniel AM, Benson PL, Roesener GH, Martindale J. An integrated computer-based system to support nicotine dependence treatment in primary care. Nicotine & Tobacco Research. Apr. 2005;7(Suppl 1):S57-66. [pmid: 16036271].
84 Forster AJ, van Walraven C. Using an interactive voice response system to improve patient safety following hospital discharge. J Eval Clin Pract. Jun. 2007;13(3):346-351. [pmid: 17518797].
85 Piette JD. Interactive voice response systems in the diagnosis and management of chronic disease. Am J Manag Care. Jul. 2000;6(7):817-827. [pmid: 11067378].
86 Piette JD, Datwani H, Gaudioso S, et al. Hypertension management using mobile technology and home blood pressure monitoring: results of a randomized trial in two low/middle-income countries. Telemedicine Journal & E-Health. Oct. 2012;18(8):613-620. [pmid: 23061642].
87 Handley MA, Shumway M, Schillinger D. Cost-effectiveness of automated telephone self-management support with nurse care management among patients with diabetes. Ann Fam Med. Nov–Dec. 2008;6(6):512-518. [pmid: 19001303].