# METHODS

## TOPIC DEVELOPMENT

The topic was nominated by the Office of Informatics and Analytics. The research questions for this systematic review were developed after a topic refinement process that included consultation between investigators, stakeholders, and content experts.

Key Question #1. How does the use of consumer health information technologies (CHIT) by non-professional caregivers of adult patients with chronic illnesses or disability, or by such patients who rely on a non-professional caregiver, affect the following outcomes:

a. Caregiver-centered outcomes?
b. Patient-centered outcomes?
c. Process measures?
d. Healthcare utilization outcomes?

Key Question #2. What lessons can be learned from studies evaluating consumer health information technologies (CHIT) that specifically target the parents/caregivers of children?

Key Question #3. What are the major gaps in the consumer health information technology literature serving non-professional caregivers of adult patients with regards to technology development, availability, and/or evaluation?

## SEARCH STRATEGY

To systematically identify relevant articles, a research librarian conducted electronic searches of multiple databases (MEDLINE^®^ via PubMed^®^, Embase^®^, IEEE Xplore, AMIA Symposium Proceedings, Healthcare Information and Management Systems Conferences, Med 2.0, and Health 2.0) using terms for non-professional caregivers and mobile applications, including but not limited to terms for handheld/tablet computers, Internet based, wireless/mobile technology, iPad, cellular/mobile/android/smart phone, m-health, SMS, text messaging, and informatics application. Appendix A shows the search strategy and the initial yields from each database. We obtained additional articles from systematic reviews, reference lists of pertinent studies, reviews, editorials, and by consulting experts.

We conducted a primary review of the literature yielded by the electronic search, and manually screened the bibliographies of included primary studies and any systematic or nonsystematic reviews that were identified.

## STUDY SELECTION

Reviewers trained in the critical analysis of literature assessed the titles and abstracts for relevance. English-language articles included at the abstract stage underwent full-text screening by one investigator (ED, KM, MF, or DK), using prespecified inclusion criteria (Appendix B). We included studies either specifically enrolling a cohort of adult, non-professional, non-robot caregivers of adult patients (KQ1) or children (KQ2) with chronic illnesses or disabilities, or reporting caregiver outcomes. As this was an exploratory review and we anticipated few controlled trials would have been published, we did not limit by study design. We defined interventions and outcomes of interest as follows:

### Interventions

Health information technologies are not currently limited by the device or operating system on which the function is available. We therefore considered technologies, applications, or functions that could be used via desktop computer, tablet computer, cell phone, smart phone, and/or personal digital assistant (PDA).

For the purposes of this report, studies were included if they utilized patient-facing and/or caregiver-facing interactive computerized health information technology. Such CHIT interventions include one or more of the applications listed in the taxonomy below:

- Education/skills: education and skill-building, such as topic-specific information, coaching modules, Question & Answer libraries, community resource information
- Self-care: decision aids, self-assessment with feedback, self-monitoring of conditions or care, patient portal access to electronic health record data
- Peer-to-peer communication: online forums, bulletin boards, listserv, email, chat and/or online support groups, with or without health professional moderation
- Caregiver-to-professional communication: secure messaging, email, chat or online forums with study staff or health professionals
- Patient-to-caregiver communication: tools that facilitate communication between caregivers, family members and care-recipients
- System transactions: transactional tools with the healthcare systems, such as medication refills, appointment requests
- Reminders: emails or text messages (SMS) to patient or caregiver on a specific issue, for example: medication reminders, notifications, or prompts on recommended care

We excluded non-interactive healthcare technology such as health education materials that are passively used and essentially reproduce paper in a digital form. We also excluded technologies consisting of access to general information such as directions, phone numbers, benefits review, and available services.

Studies that involved only telephony, interactive-voice-response, or synchronous telehealth interventions only were excluded in the report. We also excluded fixed home-monitoring technologies such as smart-homes, vitals-monitoring, GPS and other location-monitoring, and monitoring systems for patient falls.

### Outcomes

The outcomes of interest were as follows:

1. Caregiver-centered outcomes: caregiver satisfaction, caregiver burnout, caregiver quality of life scores, caregiver depression/anxiety scores.
2. Patient-centered outcomes: patient satisfaction, patient activation, functional status, quality of life; quality of patient-caregiver relationship.
3. Process measures: clinician satisfaction; caregiver perceptions of mobile technologies; usage, usability, and barriers to usage of technologies/tools/applications; communication with healthcare providers.
4. Utilization outcomes: hospitalizations, ER visits, outpatient/PCP visits.

## DATA ABSTRACTION

From the included studies, we abstracted data on the design and objectives of the study, and a brief description of the intervention. As there is not currently an agreed-upon convention for classifying the functional components of the CHIT interventions, we developed the seven categories described above. This taxonomy was adapted from multiple sources including: work performed by the Consumer Health Informatics Taxonomy Delphi study at Saint Louis University,10 prior work by one of our co-investigators,11 a systematic review performed by the Oregon Evidence-based Practice Center under contract to the Agency for Healthcare Research and Quality,1 and a report developed by the VHA Health Informatics Initiative Patient-Facing Team.12

We characterized studies by research and implementation phase in categories adapted from the definitions put forth by the UK Medical Research Council on the development of complex interventions,13 as follows:

- Development phase: studies that investigate intervention design-related outcomes (e.g., satisfaction, feasibility, usability) at an early stage of development.
- Pilot phase: studies that test user-related outcomes after the intervention has reached a relatively complete stage of development. Pilot studies are differentiated from evaluation studies if they have a small sample size (fewer than 50 participants) or if they do not report clinical outcomes.
- Testing and evaluation phase: studies that evaluate important user-related outcomes and have a sample size larger than 50 participants.

The categorization of studies by research and implementation phase is presented in Table 3.

## STUDY QUALITY

Given the exploratory aims of the key questions, and because the yield of literature was largely descriptive, qualitative, and heterogeneous in a number of characteristics, we did not formally assess the internal validity of studies.

## DATA SYNTHESIS

We compiled a narrative synthesis of findings, highlighting studies that evaluated caregiver outcomes and describing the common characteristics and themes that emerged across studies and disease categories.