# INTRODUCTION

The Department of Veterans Affairs (VA) recognizes the essential contribution of non-professional caregivers, who are an important source of physical, emotional and other support to ill or injured Veterans, including facilitating the ability for Veterans to remain in their homes. With the increased numbers of Veterans who require care and assistance for traumatic brain injuries (TBI), physical impairments, serious mental illness, and dementia there is a growing demand for spouses, parents or other family members and friends to assume the role of caregiver. Given the responsibility and diversity of tasks, and the ever-increasing reliance upon them by the healthcare system, caregivers themselves face impacts on their own quality of life, physical and mental wellbeing, and ability to manage their own healthcare needs. These impacts have been shown to be more frequent and severe for the caregivers of patients with illnesses such as dementia, neurologic disorders, and paralysis and likely have implications for Veterans’ health status as well.

Health information technology advocates have long heralded the benefits of computerized tools used by patients and families for the delivery of healthcare information, education, and behavioral interventions. Opportunities for electronic health-related tools to engage patients in their healthcare and improve their health continue to increase as the consumer technology market expands rapidly and Internet penetration rises. However, the practical value and actual use of tools is challenged by a number of factors.1–3 To be utilized as intended, consumer health information technology (CHIT) needs to be perceived as valuable, convenient, and relatively intuitive to use. Finally, these tools need to “fit” into an individual’s workflow; for a patient with a medical condition, this represents seamless integration into one’s activities of daily living.4

While a patient may not have access to technology, a loved one or caregiver could potentially access electronic information and tools on a patient’s behalf. It is estimated that 34 to 52 million American adults provide home caregiving to another individual at some point in any given year.5 Non-professional caregivers are typically not members of a licensed profession such as nursing, medicine, social work or psychology; instead, they are often family members or friends who either volunteer or work for small wages in order to coordinate care for the patient. Caregiver tasks range from basic (meal preparation, transportation to appointment) to more skilled (assistance with physical transfer, healthcare coordination, medication dispensing) and often require non-traditional work hours. Caregivers, in fact, increasingly look to the Internet for support and assistance with these tasks. According to Pew Internet & American Life national surveys, nearly half of those looking for health information online reported that their last search was on behalf of someone else.6 In the same surveys, 70 percent to 80 percent of caregivers sought health information online, and 26 percent sought peer support online with other caregivers.7

Gaps remain in technology access across populations. Internet access continues to climb among young and middle-aged adults, yet those aged 65 and older with less than a high school education or living in a rural area continue to have lower rates of access.8 Yet gaps in access continue to narrow and consumer demand for connecting to online information increases. Internet access increased from 46 percent of all U.S. adults in 2000, to 78 percent in 2010. Veterans and non-Veterans use the Internet at the same rate.9 A total of 83 percent of adults now own a cell phone, with 77 percent ownership among those with an annual income under $30,000, and 56 percent among those aged 65 and older. Notably, the proportion of black or non-white Hispanic adults who own a cell phone was higher than the general population (44 versus 35 percent) as of May, 2011.^8^

The Veterans Health Administration (VHA) is developing applications for mobile devices intended for use by caregivers of chronically ill or disabled Veterans. The objective of this report is to identify studies of consumer health information technology applications that aim to support the needs of non-professional caregivers, examine the usage and effects of CHIT applications on caregiver burden and patient outcomes of interest, and identify gaps in the literature. Because some of the earliest research in caregiver needs and support is in pediatric populations, we also reviewed the pediatric literature to evaluate potential caregiver technology applications that may be further advanced or more rigorously evaluated than in the literature pertaining to caregivers of adult patients, and discuss parallels that can be drawn from pediatric literature.