# DISCUSSION

As the need for most cost-effective and resource-limited healthcare services gains greater urgency, the VA plans to expand CHIT web and mobile applications for patients and caregivers is essential. A small but growing body of literature examines CHIT interventions developed and tested for non-professional caregivers. Overall, a broad diversity of interventions has been identified; the majority were multi-component online tools intended to improve knowledge, skills and coping, and provide social support of caregivers. Many of these interventions offered communication functions such as online peer support groups, email access to clinicians such as nurse specialists, and educational content promoting stress-relief, wellbeing, and coping skills.

Studies also reported a broad diversity of outcomes with little consistency, including patient-centered outcomes, usability, usage, and user-perceptions. The one exception being that user satisfaction was frequently reported. In all, only six studies in seven publications reported caregiver burden, strain or other caregiver-centered outcomes in the adult literature.16,18,20,23,26,38 Given the heterogeneity of interventions and measured outcomes, as well as of the evaluative methodologies used, it is difficult to draw over-arching conclusions regarding the impact of these technologies on caregivers, patients, or health systems.

Common intervention components

Online support groups were common among the interventions, and often the most frequently used component. Online support groups were typically threaded discussions on the website or group emails that facilitated asynchronous communication. Only one intervention provided real-time, synchronous communication in an online chat room so that multiple family members of a schizophrenic patient could participate in an online, professionally-mediated group therapy session despite the family members being in disparate locations.33Asynchronous, online support groups have advantages compared to their in-person counterparts such as mitigating obstacles of distance and time-constraints, as discussed previously.

Formal online support groups with restricted membership enrollments that are organized around specific applications and interventions may have benefits not seen in the informal, loosely structured, Internet interest groups, message boards, and chat rooms more typically seen on the web.23 CHESS investigators suggested that while the latter builds community around a shared condition or illness, formal online support group participants experience an increased sense of belonging as a result of restricted group membership, association with a single institution or organization, linked educational components, and shared clinical providers. Multiple studies also speculated on the benefits of professionally-mediated online discussions.27,28,32,33,38 Usually, the participating professional was a nurse specialist prompting discussion with thought-provoking questions or providing a clinical perspective to the online support group. Finn et al. believed that such a curator role was essential to re-direct misinformation.42 Rotondi et al. suggested that a curator may be necessary to quell negative comments, although in their experience, such events were rare.34 The benefits and unintended consequences of a moderator within a peer support function persist as an issue.

Applications allowing users to pose questions to a clinician were frequently included in the interventions. In the adult literature, interventions provided this functionality via an email to a nurse specialist from the website; none used alternative technology such as SMS/text messaging or web-based forms. In the pediatrics literature, use of SMS/text messaging in the evaluated intervention was quite common. A possible explanation is that parents in the pediatric literature are likely younger on average than their counterparts who are caring for adults with chronic illnesses. Thus, parents of young children and adolescents may be more familiar with current mobile phone and computing technologies. Regardless, caregivers appreciated the access to clinicians both through mediated online discussion groups and email “Ask an Expert” functions as it increased their perceptions of support and self-confidence.73

Providing distinct, parallel, private online support groups each for caregivers and patients – that was inaccessible to the other – was emphasized by two studies.34,38 Caregivers in particular held that they were “better able to voice their concerns in a separate forum” and that this was crucial to promote candid, reflective online discussions.

Generalizability

Many studies may reflect utility in highly selected populations. Most studies do not report details regarding the recruitment process, thus it remains unknown how many potential-users did not sign-up for the study, and how they might differ from the study population. For example, the only adult study reporting this data found that as many as 45 percent of those approached declined to sign-up because they were too busy, under too much stress, or did not see utility in the intervention.18

Several studies questioned whether Internet-based applications are appropriate for all users. Concerns include a lack of human contact in online communications;28 online support groups may not provide the equivalent emotional support of in-person groups;34 caregivers may not welcome outside, non-familial support;30 caregivers may reject technology-based support because it is too costly, of insufficient quality, or not geared to their routines and preferences; and replacement of face-to-face interactions with Internet applications may not be appropriate for caregivers who are particularly overstretched and overburdened, as such individuals may require more active support than can be provided online.41 Some of the most highly valued components, such as online support groups, might have less benefit in younger populations that are already comfortable with using existing social networking applications, such as Facebook.

Some studies included accommodations specifically meant to increase intervention applicability for older caregiver populations,15,41 but many studies reported on caregiver users with a mean age of 55 to 60 years. Magnusson et al. corrected a common misconception in their assertion that the elderly are not inherently negative about technology but, instead, require additional training and learning time, and increased computer/Internet access and support compared to younger users.73 Older caregivers may also benefit from applications with special accommodations for aging vision and manual dexterity.

The applicability and transferability of the interventions to a VA population remain unclear as only one study specifically evaluated Veterans. Many of the interventions could conceivably be applicable to caregivers of Veterans. For example, a number of interventions targeted conditions frequently seen in Veteran populations such as dementia, cancer, and traumatic brain injury.

While several studies detailed their security procedures,17,18,32,33,35 many studies provided relatively little information. Whether these procedures meet VA’s standards for privacy and information security would need to be determined. However, no studies reported privacy concerns from a patient or caregiver perspective.

Additional barriers to technology implementation

Some investigators raised specific concerns about incorporating Internet technologies in to the collection of care services already being provided. Among these were that users will still have time constraints that may preclude taking full advantage of online resources,23 the challenges of designing tailored resources for a broad diversity of users with different cultural backgrounds,34 complications of medical practice when users/patients may reside in neighboring states in which their providers are not licensed,35 and systems to adequately manage emergencies that are revealed online (such as suicidality).33

User experience

Technology development infrequently involves the end user, often resulting in underutilization or rejection of the intervention.41 Many investigators asserted that patients and caregivers should be included in development of intervention content, not just to ensure harmonization with the caregivers’ current life process and perception of need,30 but also to “validate and reinforce the importance of their role.”41 Several researchers described qualitative, observational data regarding the types of content that caregivers desired. Keaton et al. state that adults learn experientially, and need information that is immediately useful and relevant to their situation.28 Pierce et al. found that caregivers wanted additional information about the care-recipients’ medical conditions.31 Rotondi et al. described their unpublished data suggesting caregivers want better skills for dealing with the medical, cognitive, and behavioral sequelae of illness and injuries, and assistance identifying additional community and financial resources.

Formal usability testing was seldom described in the literature; however, tools do exist, including the Website Analysis and Measurement Inventory (WAMMI)39 and System Usability Score (SUS).32 In addition, a U.S. government website provides other tools for measuring usability, as well as descriptions of underlying principles.77

Inability of users to access website content was frequently acknowledged in studies. In some cases, these issues could not be overcome despite provision of computers, Internet connectivity and/or training to users. Familiarity and comfort with technology was cited as a possible explanation, which may disproportionately affect older adults. Magnusson et al. asserted that the elderly are not inherently negative about technology but have increased challenges due to less computer access, requiring longer training, and a lack of confidence.73 Additional allowances for training and education may overcome such barriers, and technology can accommodate for the physical deterioration of age or chronic illness such as decreased vision and mobility.

Three pediatric studies raised potential concerns regarding online support groups. Parents of children with cancer experienced distress to postings about the death of a child.51 Two other studies cited the need for a critical mass of participants to foster active discussion.32,50

## LIMITATIONS

In setting out to perform a systematic review of a new healthcare technology, a chief limitation is the pace of change. The healthcare mobile application market is seeing unprecedented growth and dissemination. Although research is ongoing, the evidence base within the published literature has yet to appear. Thus, while this was intended to be an expansive review, we noted that many relatively new technologies such as text-messaging, tweeting, and interactive, game-based applications were not represented in the articles captured and reviewed.

Our review focused on CHIT used by caregivers; we acknowledge there are technologies tested only in patients that could conceivably be used by caregivers, but these were outside of the scope of this review. Of note, our review scope also excluded telehealth and telemedicine interventions, even though these are interventions that could potentially be adapted to mobile platforms – these are the subject of other reviews.78–81 The review also excluded interactive voice response, or IVR, technology. IVR systems are automated, computerized telephonic interventions that deliver individualized messages and collect feedback from targeted users through voice recognition and telephone keypads. Though outside the scope of our review, IVR has promise as a CHIT intervention, particularly in populations with lower access to the Internet or smartphones or for delivering less complex interventions. IVR has been assessed in a variety of settings and medical conditions relevant to VA, including depression,82 tobacco use,83 post-discharge care,84 heart failure and diabetes.85 IVR appears acceptable to patients including those with mental health conditions,85 and has shown positive effects on patient behavior related to screening, prevention, treatment follow-up and medication reminders.86,87

The lack of a common taxonomy for CHIT might have made it more difficult to find all potentially relevant intervention studies as they may have been indexed in ways that we did not cover in our search strategy. We used a broad search strategy (Appendix A), and we searched bibliographies of included articles. Finally, as this is primarily an exploratory review, we did not conduct formal quality assessment of included studies. Many of the included studies represented pilot or developmental phase interventions with numerous methodologic weaknesses such as lack of control groups and small sample sizes. The results of this review should not be interpreted to provide definitive evidence about intervention efficacy.

## CONCLUSION

There is a growing literature of CHIT interventions that are being developed for non-professional caregivers. Overall, a broad diversity of interventions has been identified; the majority were multi-component online tools intended to improve knowledge, skills and coping, and provide social support of caregivers. Many of these interventions offered communication functions such as online peer support groups; email access to clinicians such as nurse specialists; and educational content promoting stress-relief, wellbeing, and coping skills. However, usability testing was infrequently reported. Given the heterogeneity of interventions and measured outcomes, as well as of the evaluative methodologies used, it is difficult to draw over-arching conclusions regarding the impact of these technologies on caregiver, patient, or health system outcomes. Formal usability testing can identify important challenges and should be incorporated more often in the development process. Patients and caregivers should be involved in the design and improvement of interventions.

Below is a list that summarizes the emerging themes and future research directions for CHIT interventions:

- Consumer health technologies for caregivers may improve caregiver strain, coping strategies, self-efficacy, intention to obtain additional support, depression, anxiety, and anger.
- Online access to expert care from healthcare providers via text-messing, Q&A, FAQs, etc. are also highly valued and may supplement existing communications.
- Text-messaging systems can reach significant numbers of caregivers and have been examined as a way to enhance compliance to medications and preventive health actions.
- The asynchronous nature of communication in online peer support groups and text-messaging may facilitate participation by mitigating geographic and temporal barriers.
- Online peer support groups and chat rooms were the most-used and most-valued components in several interventions.
- In online support groups, anonymity through the use of a Screen Name or User ID was valued by caregivers and patients, and should be incorporated.
- Privacy issues did not emerge as a major concern for caregivers and patients and should not necessarily be perceived as a barrier to the development of consumer health technologies.
- Technical barriers and lack of familiarity with technology are the most frequently cited reasons for failure to participate in a technology intervention.

Future directions:

- Consumer health technologies may reduce the frequency of emergency visits and hospitalizations.
- Benefits of consumer health technologies may occur with even limited, and short-term use.
- User-centered design likely improves the utility, usability and usage of technology implementations; caregiver and veteran participation in the design and development of consumer health technologies should be solicited.
- Pre-implementation planning and budgets should assign resources to assist caregivers and veterans with access issues and ongoing technical support, and programs should assess the optimal levels of technical assistance and training required.
- Programs should assess how technologies can be tailored to the language and cultural needs of the caregiver and Veteran.
- Study whether formal online peer support groups exclusive to the VA have advantages over existing informal online interest groups.
- Caregivers and patients may seek immediately useful and relevant information online, such as skills improvement and assistance identifying community and financial resources. Future technology implementation interventions should explore their utility and methods for keeping information current.
- There is a need for more studies using mixed-methods and formative evaluation methods to help clarify effects and implementation strategies for these complex health technology interventions.
- There are several future research questions that may be of interest:
  ○ What are the optimal methods for implementing consumer health technologies in existing healthcare systems?
  ○ Does the use of consumer health technologies such as chat rooms, online peer support groups, and text messing with providers replace or complement face-to-face interactions?
  ○ How are consumer health technologies integrated into the day-to-day lives of caregivers?
  ○ How do caregiver demographics affect the user experience?
  ○ Are there differences between caregivers and Veterans in the user experience?
  ○ Develop tools to enhance caregiver-Veteran communication.
  ○ Studying the implementation of interventions within the VA using tools with broad reach, such as My HealtheVet.