# DEFINITIONS AND ABBREVIATIONS

The following abbreviations are used throughout this document:

ACTION: Assisting Carers using Telematics Interventions to meet Older Persons’ Needs
AD: Alzheimer’s disease
ADHD: Attention deficit and hyperactivity disorder
BSFC: Burden Scale for Family Caregivers
BSI: Brief Symptom Inventory
CAI: Caregiver Appraisal Inventory
CG: Caregiver, non-professional family members, friends, or community members
CHESS: Comprehensive Health Enhancement Support System
CHIT: Consumer health information technologies, defined as interactive technologies that provide targeted or tailored health information and/or self-management tools or applications designed to support consumers’ management of their health, health care, or health information
CR: Care-receiver/care-recipient, whether adult, child, or patient
CSES: Caregiver Self-Efficacy Scale
CSP: Customized Sleep Profile
CVA: Cerebrovascular accident, stroke
ER: Emergency room
HPN: Home Parenteral Nutrition
ICSS: Internet-based Caregiver Support Service
ICT: Information Computing Technology
ICU: Intensive care unit
IRC: Internet resources
IVR: Interactive voice response
KQ: Key question
NR: Not reported
OFPS: Online Family Problem-Solving
PCP: Primary care physician
PDA: Personal digital assistant
PDF: Portable Document Format, a file format used to represent documents for display on computers, smartphones and tablets
PIES: Prostate Interactive Education System
PTSD: Post-traumatic stress disorder
QOL: Quality of life
RCT: Randomized controlled trial
SCL-90: Symptom Checklist-90
SMS: Short Message Service, a protocol that supports text messaging for mobile phones
SNF: Skilled nursing facility
SRG: Stress-Related Growth
SUS: System Usability Scale
SWLS: Satisfaction with Life Scale
TBI: Traumatic brain injury
TOPS: Teen Online Problem Solving
Tx: Treatment
VA: Veterans Affairs, United States Department of
VHA: Veterans Health Administration
WAMMI: Website Analysis and Measurement Inventory
WECARE: Web Enabled Caregiver Access to Resources and Education