# INCLUSION/EXCLUSION CRITERIA

1. Is the full text of the article in English?
Yes | Proceed to #2
No | Code X1. STOP
2. Is the article a primary study that presents findings based on original data collection; or a systematic review of primary studies?
Yes | Proceed to #3
No | Code X2. Go to #6
3. Does the article evaluate the effectiveness of a targeted consumer health information technology (CHIT) intervention listed below in the PICOTS?
Yes | Proceed to #4
No | Code X3. Go to #5
4. Does the study population include non-professional, human/non-robot caregivers of patients with chronic illness or disability, or are caregiver-centered outcomes reported as a primary outcome?
Yes, adult patients | Code I3/A. STOP
Yes, child patients | Code I3/C. STOP
No | Code X4. Go to #6
5. Is the article a primary study or systematic review evaluating the effects of telephony, interactive voice response, or telehealth interventions?
Yes | Code I5. STOP
No | Code X5. Go to #6
6. Is the article possibly useful for background/discussion? | Code B. STOP

## PICOTS

Population: Non-professional, non-robot caregivers of adult patients with chronic illnesses, and/or parents of children with healthcare needs.

Intervention: Self-directed mobile applications for use on smart phones, personal digital assistants (PDAs) and tablet computers, including: interactive or individually tailored web-based interventions, decision aids, and risk assessment software; chat and online support groups; secure messaging; or other portable or home-based interactive information tools whose purpose is to facilitate communication, coordination, or tailored education in order to support the emotional, spiritual, organizational, management, and healthcare needs of non-professional caregivers of patients with chronic illnesses or health risk factors. Non-interactive educational media (e.g., E-pamphlet) that provide information only are excluded.

We excluded studies focused on telephony, interactive-voice-response, synchronous telehealth interventions, and fixed home-monitoring technologies such as smart-homes, vitals-monitoring, GPS and other location-monitoring, and monitoring for patient falls.

Control: Usual care (use of paper forms and educational materials, in-person visits).

Outcomes:

1. Caregiver-centered outcomes: caregiver satisfaction, caregiver burnout, caregiver access, caregiver quality of life scores, caregiver depression/anxiety scores.
2. Patient-centered outcomes: patient satisfaction, patient activation, functional status, quality of life; quality of patient-caregiver relationship.
3. Process measures: clinician satisfaction; caregiver perceptions of mobile technologies; usage, usability, and barriers to usage of technologies/tools/applications; communication with healthcare providers.
4. Utilization outcomes: hospitalizations, ER visits, outpatient/PCP visits.

Timing: No restrictions.

Setting: Outpatient (home, assisted living, adult foster care), excluding skilled nursing facilities.