# SEARCH STRATEGY

Search conducted in MEDLINE^®^ via PubMed^®^ on 12/9/2011

Concept | Search# | Search String | Citations
Non-Professional caregivers | #60 | ((“Family”[Mesh]) OR “Caregivers”[Mesh]) OR “Home Nursing”[Mesh] | 220979
Non-Professional caregivers | #77 | (((caregiv*[Title/Abstract]) OR “care giving”[Title/Abstract]) OR “care giver”[Title/Abstract]) OR care givers[Title/Abstract] | 28393
Non-Professional caregivers | #78 | (#77) OR #60 | 235910
Mobile apps | #80 | ((“Computers, Handheld”[Mesh]) OR “Cellular Phone”[Mesh]) OR “wireless technology”[Mesh] | 4152
Mobile apps | #81 | iPad OR handheld OR interactive OR mobile computing OR smart phone* OR mobile phone* OR mobile technolog* OR m-health OR internet based OR personal digital assistant* OR online OR sms OR iphone OR android OR text messag* OR tablet computer OR informatics application OR app | 100411
Mobile apps | #82 | (#81) OR #80 | 101517
Union of concepts | #83 | (#82) AND #78 | 2147

Search for specialized databases and grey literature conducted 12/9/2011 and 4/30/2012

Specialized Databases and Grey literature sources searched
Database | Search | Hits
AMIA Proceedings http://proceedings.amia.org Searched 12/9/2011 | “caregiv*” | 268
IEEE Xplore http://ieeexplore.ieee.org Searched 12/9/2011 | “caregiv*” | 266
Healthcare Information & management Systems (HiMSS) conferences and website http://www.himss.org/ASP/index.asp Searched 4/30/2012 | “caregiver” OR “caregiving” | 2
Med 2.0 (abstracts from 2008 – 2012) http://www.medicine20congress.com/ocs/index.php/med/med2012 Searched 4/30/2012 | “caregiver” OR “caregiving” | 2
Health 2.0 (abstracts from 2007 – 2011) http://www.health2con.com/conferences/ Searched 4/30/2012 | “caregiver” OR “caregiving” | No results