# SUMMARY AND DISCUSSION

## SUMMARY OF EVIDENCE

We found 31 studies examining the effects of mTBI in Veteran and military populations. In general, though cognitive, physical, and mental health symptoms were commonly reported by Veterans and members of the military following an mTBI, there was little evidence that symptoms were more commonly reported by study participants with mTBI than similar participants without mTBI. However, the evidence base is weakened by inconsistent findings, methodologic shortcomings of many studies, and variation in outcomes considered and outcome measurement approaches. Therefore, conclusions drawn from this body of literature are uncertain, likely to change given additional research in the future, and should be interpreted with caution.

Mental health problems are a serious concern for Veterans and members of the military with mTBI, though the extent to which these outcomes are uniquely related to mTBI versus other deployment-related illnesses are not clear. Posttraumatic stress disorder (PTSD) is one of the most common mental health disorders among Veterans of wartime service, affecting approximately 15% of Veterans of all eras.40 A recent systematic review estimated the overall prevalence of comorbid TBI and PTSD among OIF/OEF Veterans at 5-7%,41 and among Veterans with histories of TBI, rates of PTSD range from 33-65%.41-44 Furthermore, having both PTSD and TBI may adversely affect functionality more than suffering from either disorder alone.45

The high prevalence of comorbid PTSD and mTBI are likely related to both event-related factors and neuropsychiatric symptom overlap between disorders.46 Modern warfare involving multiple deployments and high rates of blast exposure has greatly increased service members' risk of TBI and PTSD.47 In addition, there is evidence from neuroimaging studies that PTSD and TBI affect similar areas of the brain, including the prefrontal cortex, hippocampus, and amygdala.47,48 Regardless of etiology, the overlap in the presentation of mTBI and PTSD can be accounted for at least in part by shared symptoms. In particular, core symptoms of both PTSD and postconcussive syndrome include problems with concentration/attention and memory, sleep disturbance, and irritability.49,50 Moreover, cognitive complaints and objective neurocognitive deficits are common among individuals with PTSD, even in the absence of a history of TBI,48,51-54 including problems with memory, concentration/attention, and problem-solving.

We found a very limited evidence base examining functional and social outcomes suggesting that one fifth to one quarter of Veterans with mTBI experienced unemployment, sleep disturbance, or lack of emotional support. Whereas more severe levels of TBI are identified immediately post-trauma, cases of mTBI are often unidentified and untreated until after military discharge, at which point Veterans may begin to recognize problems like trouble reintegrating into work or school or difficulties maintaining familial or social relationships. Longitudinal studies have found impairments ranging from difficulty maintaining leisure interests and friendships, to vocational instability, poor life satisfaction, and poor quality of life among individuals who have incurred mTBI.55,56 Individuals' social and physical environments can either help or hinder recovery of full functional capacity after mTBI. Research has found factors like social support, family adjustment and cohesion, life stressors, and receipt of compensation for disability to be associated with functional outcomes among individuals with mTBI.57

The VA will be providing life-long care for a large number of OEF/OIF/OND Veterans who have sustained mTBI. In some cases, the VA will also provide care for the Veterans' informal/family caregivers.58 The long-term resource needs of OEF/OIF/OND Veterans are likely substantial; however, these resource needs are possibly related to a variety of factors including comorbid conditions and other consequences of deployment and not uniquely related to having experienced an mTBI. The majority of data on costs and resource utilization of individuals with TBI comes from civilian studies and examines those with moderate-to-severe TBI, for which follow-up care and rehabilitation needs are great and disability is common. Little is known about long-term costs and needs for those with mTBI, particularly military members or Veterans with deployment-related mTBI. Although most outcomes studies of civilians have found that symptoms and sequelae of mTBI resolve within one year after the injury,59 different contextual factors including mechanism of injury provide only indirect comparisons to Veteran/military outcomes. It is likely that complicating deployment-related factors such as repeat mTBI events or concomitant mental health disorders such as PTSD could result in very different long-term outcomes and resource utilization for this population.

### Findings from Civilian Populations

Though the overall strength of evidence evaluating outcomes following mTBI in Veteran or military populations is low, it is noteworthy that the findings are remarkably consistent with higher quality civilian literature.59 Both bodies of research suggest that many health consequences resolve within the first few months following injury, if not sooner.

A systematic review of literature in children and adults found objective cognitive deficits associated with mTBI resolve within 2-3 months and the physical consequences of mTBI are likely limited to those which resolve within the first few days following injury.59 The authors note that though objective cognitive impairment resolves quickly, subjective cognitive complaints may linger for years for some individuals who experience mTBI. They also found that litigation or evaluation for compensation was a risk factor for worse cognitive test performance, a finding echoed by another review.60

Other systematic reviews reported similar findings. One review described insufficient and inadequate evidence for any cognitive effects of mTBI greater than 6 months following injury.61 A meta-analysis of sports-related concussion suggests that though some impairment in memory and global cognitive functioning may be present for individuals with mTBI within a week of injury, these effects are no longer present after 7 days post-injury.60 These authors also found cognitive deficits were no longer present by 3 months after injury in unselected, consecutive samples.60

A systematic review of civilian literature related to functional impairment suggests that there is not a significant impact for children with mTBI, and most functional impairment resolves within a month for adults with mTBI.59 However, this review also points out that self-reported functional impairment may last longer, up to years, in some instances, particularly when individuals are involved in litigation or compensation related to the mTBI, and when individuals experience the mTBI event as psychologically traumatic.

Pertab and colleagues conducted a re-analysis of studies included in earlier meta-analyses. This group of authors suggests that time since injury and the use of different cognitive assessment tools may have a potentially moderating effect on cognitive outcomes.62 The authors describe a range in summary effect sizes based on cognitive domain and time since injury, suggesting the possibility that some subgroups of those with mTBI may experience some objective cognitive deficits for a limited period of time following injury.

Of note, the WHO Collaborating Centre for Neurotrauma Prevention, Management and Rehabilitation Task Force has recently completed an updated systematic review examining the effects of mTBI in civilian populations. Results are likely to be reported within the next year and should further add to our understanding.

Even though the strength of evidence in civilian populations is higher, there is not enough information in that body of literature either to identify how factors such as time since injury, mechanism of injury, or number of mTBIs influence long-term outcomes.

### Use of Imaging and Biomarkers in mTBI Research

Although beyond the scope of this review, since imaging and biomarker technologies are a rapidly evolving area of research of interest to stakeholders, we will briefly summarize recent relevant research here.

Although biomarkers are increasingly being used as prognostic tools among those with moderate or severe TBI, research among those with less severe injuries has been limited.63 Efforts are focused on evaluating serum and cerebral spinal fluid during different stages of the brain injury cascade (e.g., inflammation, neuronal injury).64 As no single biomarker with discriminative characteristics has been indentified, Sharma and Laskowitz (2012) suggest that combining biomarkers may increase sensitivity and specificity.64 For further information regarding biomarkers and mTBI see Jeter et al. (2012), and Sharma and Laskowitz (2012).64,65

Recent interest has emerged regarding the possibility that returning military personnel with a history of TBI are at risk for developing chronic traumatic encephalopathy (CTE).66 CTE refers to persistent cognitive and neuropsychiatric symptoms (e.g., executive dysfunction, memory impairment, depression, poor impulse control, and dementia) secondary to chronic neurodegeneration thought to be caused at least in part by multiple TBIs.67 At present, CTE can only be identified by direct tissue examination; as such, full autopsies and immunohistochemical brain analyses are necessary for definitive diagnosis. Despite much speculation regarding blast exposed individuals being at risk for CTE, limited data currently exists in support of this relationship. Current efforts pertaining to increasing understanding regarding CTE include: creating clinical diagnostic criteria, identifying objective biomarkers, and increasing understanding regarding additional risk factors and underlying mechanisms.68

Recent literature reviews of neuroimaging in mTBI including DTI, functional,69 and metabolic imaging,70 have examined the association of imaging findings with neuropathology.71 Although brain changes resulting from mTBI are often not discernible with conventional clinical structural CT and MRI, there is a growing body of evidence that they are more readily detectible with advanced research imaging technologies, particularly DTI,72 which measures the functional integrity of white matter interconnections within the brain. A rapidly growing body of DTI investigation indicates that DTI is more sensitive to white matter injury than conventional MRI and CT, with DTI consistently detecting more abnormalities than conventional CT or MRI across multiple mTBI studies. As would be expected from the animal model and neurocognitive assessment literature,71 acute and subacute structural and functional imaging changes are demonstrated. However, abnormalities have also been demonstrated at chronic stages, suggesting that some patients experience long-term brain changes as well. The most common abnormalities have been shown for long association pathways including the corticospinal tract, corpus callosum, corona radiata, internal capsule, uncinate fasciculus, and the superior longitudinal fasciculus. Further, in some studies, DTI abnormalities correlate with cognitive performance in patients with mTBI, with general aggregate DTI abnormality correlated with executive function, memory, and cognitive processing speed. Locally specific structure-function relationships have sometimes been observed in mTBI, with damage to frontal white matter associated with executive function and attentional performance, and temporal tract changes associated with decreases in memory performance. Some more recent imaging studies support the notion of persistent postconcussive symptoms (PCS), with observable pathophysiological findings correlated with PCS. Supportive of these DTI findings, many fMRI studies found activation differences between individuals with mTBI and individuals in the control group during cognitive and behavioral tasks consistent with DTI findings, although many studies failed to show associated significant differences in task performance.69 The various metabolic imaging techniques are less well investigated in mTBI, but initial results suggest that these techniques show promise as investigative and diagnostic tools.70

Although rapidly growing, there remain several limitations for mTBI neuroimaging research. It is largely made up of cross-sectional studies with small samples, and there is a great deal of method and design variability with respect to such factors as time period of scanning post-injury, brain regions examined, magnet strength, non-imaging outcome variables, and methods of analyses, resulting in differences across studies in both anatomical location of observed brain alterations and the nature of these alterations. Despite considerable consistency in its main findings, this body of research is still relatively new and there remain as-yet unresolved discrepancies. For instance, some DTI studies show increased fractional anisotropy (FA), while others show decreased FA. Also, many fMRI studies failed to show associated significant differences in task performance associated with significant task-related activation differences between patients and control participants.69 Imaging studies nonetheless are consistent in providing evidence of small and subtle brain injuries in mTBI that are often, although not always, associated with symptoms and cognitive performance. This evidence would not be possible if conventional MRI and CT scans alone were used to establish and characterize brain injury; it requires more advanced and sophisticated imaging methods such as DTI and fMRI that are sensitive to the effects of diffuse axonal injury and altered metabolic function to delineate these abnormalities.

### Clinical Considerations

The best available evidence, which is of low quality, suggests that many symptoms that patients ascribe to mTBI may be related to comorbid mental or physical health concerns, or to other factors such as readjustment to civilian life following deployment or injury beliefs and perceptions.73 Difficulties related to post-deployment adjustment underscores the need to engage recently returned Veterans and members of the military quickly in efforts to identify physical and mental health problems and provide appropriate re-integration services. Patients should be encouraged to engage in treatment for these comorbid concerns with the best available evidence-based treatments (e.g., evidence-based psychotherapy to treat PTSD).

Administrators setting policy for treatment of military-related mTBI should be cautioned to treat the available evidence as limited and subject to change depending on findings from future, more methodologically rigorous studies. Policy based on the best available evidence should likely encourage the treatment of comorbid conditions that commonly occur for Veterans and members of the military who have experienced deployment (e.g., treatment for PTSD, substance use disorders, headaches, sleep disorders, and other post-deployment concerns).

Given the lack of large, good-quality observational studies with adequate follow-up it is very difficult to estimate the long-term cognitive effects of mTBI. However, the current evidence base suggests that cognitive deficits are not common, particularly more than three months after injury. Therefore, should individuals with mTBI continue to experience ongoing cognitive deficits following first-line treatment for co-occurring symptoms and disorders such as PTSD, further testing such as neuropsychological or neurological evaluations or imaging might be warranted.

## LIMITATIONS AND RECOMMENDATIONS FOR FUTURE RESEARCH

The available literature reporting consequences of mTBI in Veteran and military populations is based on low quality observational studies and provides low strength evidence for the associations synthesized in this systematic review. Notably, not all outcomes of potential interest to stakeholders were found in the literature base (e.g., costs). There is insufficient data to determine the presence or absence of an effect for these outcomes, and further research is warranted.

One of the major limitations of this literature is the inadequate reporting of and accounting for time since injury among Veterans and military members, and therefore it is not possible to construct an accurate picture of mTBI consequences over time for this population. This body of literature is also likely subject to participant recall bias due to the cross-sectional, retrospective nature of almost all included studies. Participants are likely unable to accurately recall symptoms and timeframes so long after one (or more) mTBI events. Future research should take advantage of available VA and DoD databases that have time since injury information and include this variable in the analysis of mTBI consequences on an individual participant level. Similarly, such databases should be used to examine the possible effect of multiple mTBI events as this is a common occurrence for many individuals who were part of OEF/OIF conflicts. Additionally, a large prospective cohort study would be better able to identify factors associated with outcomes in mTBI populations.

A related limitation of the body of literature relates to how data is presented in included studies. Very few studies reported the actual prevalence of symptoms or conditions; most studies simply reported mean scores for the entire study group. This latter approach can provide useful information for determining whether there is a unique contribution of mTBI versus outcomes being affected by more general deployment or combat exposure factors. However, a lack of prevalence estimates limits an accurate description of the population, particularly when a goal of stakeholders is to estimate numbers of Veterans who will be affected by specific outcomes and utilize related treatment services. Future research should not only report mean scores for subgroups, but also report proportions of individuals with clinically significant impairment for each outcome. This recommendation is particularly relevant to the body of research on cognitive outcomes, as the vast majority of this literature describes differences based on means rather than reporting the proportion of individuals who obtain scores indicating impaired functioning. For cognitive outcomes in particular, impairment is ideally determined not only by standardized scores within a certain range, but also by comparison to pre-injury (baseline) functioning. Studies should report this intra-individual change as part of any cognitive findings so that accurate estimates of mTBI-related cognitive impairment are reported.

Few studies presented data on all outcomes of interest to the stakeholders of this review, and few studies reported their outcome reporting rationale. Most studies relied on clinical datasets, which are generally not maintained for research purposes, rather than research databases or registries. The use of these datasets can be efficient relative to primary data collection but typically do not contain all variables of interest in a given scientific inquiry. It is likely that many studies only included outcomes of relevance to the authors' particular study questions, though it is impossible to know whether some studies did not report outcomes given a lack of association with mTBI. There is a pressing need for large cohort studies of Veterans with and without mTBI that prospectively collect data on all risk and protective factors, and all outcomes of interest. Such studies would be relatively costly but would result in higher-quality evidence on which more definitive conclusions could be based.

Although a strength of this review was that many of the included studies relied on well-validated measures commonly used with Veteran/military populations, many of the clinical outcomes relied solely on self-reported outcomes, often obtained from single questionnaire items. Self-report data is often the only way to assess certain outcomes such as pain. However, some notable results from this review and a review of the civilian literature59 suggest that self-reported deficits are more likely to be reported by individuals with mTBI. Assessment for mTBI is often associated with potential financial compensation, which in turn has been commonly associated with worse outcomes. Because participants are not often blinded to study hypotheses, self-reported outcomes should be interpreted with greater caution than objective findings evaluated by blinded outcome assessors. Thus, future research should consider using objective and validated assessments, blinded outcome assessors, patient blinding to study hypotheses, and accounting for compensation factors whenever possible in order to reduce bias associated with outcome assessment.

Additionally, future research should employ commonly used outcome assessment tools in order to facilitate the combination of results across studies for meta-analytic purposes. One of the limitations of this body of literature was the wide variety of tools used to assess each outcome. Though we reported statistically significant results from included studies, it is possible that combining studies mathematically would increase power, and effects could be detected in aggregate which were not apparent at the individual study level. In the case of this review, diversity in outcome assessment tools precluded mathematical combination of results.74

A final strength of this review was the use of clear criteria for defining mTBI. However, because the majority of studies did not assess or report imaging results, and those that did were inconsistent in their inclusion of participants with positive imaging results, we were not able to apply exclusion criteria based on positive imaging as is recommended by the VA/DoD definition of mTBI. Additionally, because of our reliance on stringent definitional criteria, we excluded many studies that purported to study mTBI populations, but did not meet the criteria for this report. The scope of this report focused explicitly on OEF/OIF/OND Veterans and members of the military meeting VA/DoD mTBI criteria; consequently, this report provides a narrow window of information on mTBI and should not be viewed as comprehensive. Findings from other systematic reviews on mTBI in civilian populations should be considered for a more complete understanding of mTBI consequences. Future primary research should clearly report criteria used to define mTBI, including assessment and reporting of imaging results. Future research should investigate the possible impact of number of mTBI events, as many studies noted that Veterans experienced multiple mTBIs, though few examined this variable as a possible moderator of outcomes. Additionally, future reviews should consider examination of differences in outcomes based on definitional criteria for mTBI, as it is possible that less stringent criteria could be associated with different results.

## CONCLUSIONS

Overall, given the low strength of evidence, it is difficult to draw firm conclusions about the effects of mTBI in Veteran and military populations. The literature reviewed here is relatively consistent with findings from the more methodologically rigorous, prospective, longitudinal studies conducted in civilian populations. Both bodies of literature suggest that though some negative outcomes occur for a significant portion of individuals who have mTBI, most objective results (e.g., objective cognitive test results) are not significantly different from control participants, and deficits that are present shortly following injury most often resolve within days to months. The literature on Veterans and members of the military suggests that many have physical and mental health symptoms, but it is not clear that those with mTBI experience more or higher severity symptoms than those without mTBI suggesting that outcomes may be influenced by other deployment-related conditions such as PTSD. The studies included in this report were low quality, cross sectional studies which did not provide consistent evidence for potential moderators of mTBI outcomes.