# REFERENCES

1 Hoge CW, Goldberg HM, Castro CA. Care of war veterans with mild traumatic brain injury--flawed perspectives. N Engl J Med. Apr. 16. 2009;360(16):1588-1591. [pmid: 19369664].
2 Ruff R. Two decades of advances in understanding of mild traumatic brain injury. J Head Trauma Rehabil. Jan-Feb. 2005;20(1):5-18. [pmid: 15668567].
3 Wood RL. Understanding the ‘miserable minority’: a diasthesis-stress paradigm for post-concussional syndrome. Brain Inj. 2004;18(11):1135-1153. [pmid: 15545210].
4 Cancelliere C, Cassidy JD, Côté P, et al. Protocol for a systematic review of prognosis after mild traumatic brain injury: an update of the WHO Collaborating Centre Task Force findings. Systematic Reviews. 2012;1:17. [pmid: 22587804].
5 Lin H, Ling S, Liu Z, Zhong X, Chen W. Preventive scleral buckling and silicone oil tamponade are important for posttraumatic endophthalmitis successfully managed with vitrectomy. Ophthalmologica. 2011;226(4):214-219. [pmid: 21893970].
6 Goldman SM, Tanner CM, Oakes D, Bhudhikanok GS, Gupta A, Langston JW. Head injury and Parkinson's disease risk in twins. Ann Neurol. Jul. 2006;60(1):65-72. [pmid: 16718702].
7 Wells GA, Shea B, O'Connell D, et al. Newcastle Ottawa scales. 2009. http://www.ohri.ca/programs/clinical_epidemiology/oxford.asp.
8 Guyatt G, Oxman AD, Akl EA, et al. GRADE guidelines: 1. Introduction-GRADE evidence profiles and summary of findings tables. J Clin Epidemiol. Apr. 2011;64(4):383-394. [pmid: 21195583].
9 Barnes SM, Walter KH, Chard KM. Does a history of mild traumatic brain injury increase suicide risk in veterans with PTSD?. Rehabil Psychol. Feb. 2012;57(1):18-26. [pmid: 22369114].
10 Belanger HG, Kretzmer T, Vanderploeg RD, French LM. Symptom complaints following combat-related traumatic brain injury: relationship to traumatic brain injury severity and posttraumatic stress disorder. J Int Neuropsychol Soc. Jan. 2010;16(1):194-199. [pmid: 19758488].
11 Belanger HG, Kretzmer T, Yoash-Gantz R, Pickett T, Tupler LA. Cognitive sequelae of blast-related versus other mechanisms of brain trauma. J Int Neuropsychol Soc. Jan. 2009;15(1):1-8. [pmid: 19128523].
12 Belanger HG, Proctor-Weber Z, Kretzmer T, Kim M, French LM, Vanderploeg RD. Symptom complaints following reports of blast versus non-blast mild TBI: does mechanism of injury matter?. Clin Neuropsychol. Jul. 2011;25(5):702-715. [pmid: 21512958].
13 Benge JF, Pastorek NJ, Thornton GM. Postconcussive symptoms in OEF-OIF veterans: factor structure and impact of posttraumatic stress. Rehabil Psychol. Aug. 2009;54(3):270-278. [pmid: 19702425].
14 Coldren RL, Kelly MP, Parish RV, Dretsch M, Russell ML. Evaluation of the Military Acute Concussion Evaluation for use in combat operations more than 12 hours after injury. Mil Med. Jul. 2010;175(7):477-481. [pmid: 20684450].
15 Coldren RL, Russell ML, Parish RV, Dretsch M, Kelly MP. The ANAM lacks utility as a diagnostic or screening tool for concussion more than 10 days following injury. Mil Med. Feb. 2012;177(2):179-183. [pmid: 22360064].
16 Cooper DB, Chau PM, Armistead-Jehle P, Vanderploeg RD, Bowles AO. Relationship between mechanism of injury and neurocognitive functioning in OEF/OIF service members with mild traumatic brain injuries. Mil Med. 2012;177(10):1157-1160. [pmid: 23113441].
17 Cooper DB, Kennedy JE, Cullen MA, Critchfield E, Amador RR, Bowles AO. Association between combat stress and post-concussive symptom reporting in OEF/OIF service members with mild traumatic brain injuries. Brain Inj. 2011;25(1):1-7. [pmid: 21117916].
18 Cooper DB, Mercado-Couch JM, Critchfield E, et al. Factors influencing cognitive functioning following mild traumatic brain injury in OIF/OEF burn patients. NeuroRehabilitation. 2010;26(3):233-238. [pmid: 20448313].
19 Cooper DB, Nelson L, Armistead-Jehle P, Bowles AO. Utility of the mild brain injury atypical symptoms scale as a screening measure for symptom over-reporting in operation enduring freedom/operation iraqi freedom service members with post-concussive complaints. Arch Clin Neuropsychol. Dec. 2011;26(8):718-727. [pmid: 21873326].
20 Drag LL, Spencer RJ, Walker SJ, Pangilinan PH, Bieliauskas LA. The Contributions of Self-reported Injury Characteristics and Psychiatric Symptoms to Cognitive Functioning in OEF/OIF Veterans with Mild Traumatic Brain Injury. J Int Neuropsychol Soc. May. 2012;18(3):576-584. [pmid: 22390876].
21 Gaylord KM, Cooper DB, Mercado JM, Kennedy JE, Yoder LH, Holcomb JB. Incidence of posttraumatic stress disorder and mild traumatic brain injury in burned service members: preliminary report. J Trauma. Feb. 2008;64(2 Suppl):S200-205. discussion S205-206. [pmid: 18376167].
22 Gordon SN, Fitzpatrick PJ, Hilsabeck RC. No effect of PTSD and other psychiatric disorders on cognitive functioning in veterans with mild TBI. Clin Neuropsychol. Apr. 2011;25(3):337-347. [pmid: 21360415].
23 Gottshall K, Drake A, Gray N, McDonald E, Hoffer ME. Objective vestibular tests as outcome measures in head injury patients. Laryngoscope. Oct. 2003;113(10):1746-1750. [pmid: 14520100].
24 Kelly MP, Coldren RL, Parish RV, Dretsch MN, Russell ML. Assessment of acute concussion in the combat environment. Arch Clin Neuropsychol. Jun. 2012;27(4):375-388. [pmid: 22491730].
25 Kennedy JE, Cullen MA, Amador RR, Huey JC, Leal FO. Symptoms in military service members after blast mTBI with and without associated injuries. NeuroRehabilitation. 2010;26(3):191-197. [pmid: 20448309].
26 Kennedy JE, Leal FO, Lewis JD, Cullen MA, Amador RR. Posttraumatic stress symptoms in OIF/OEF service members with blast-related and non-blast-related mild TBI. NeuroRehabilitation. 2010;26(3):223-231. [pmid: 20448312].
27 Lew HL, Pogoda TK, Hsu PT, et al. Impact of the “polytrauma clinical triad” on sleep disturbance in a department of veterans affairs outpatient rehabilitation setting. Am J Phys Med Rehabil. Jun. 2010;89(6):437-445. [pmid: 20489391].
28 Lippa SM, Pastorek NJ, Benge JF, Thornton GM. Postconcussive symptoms after blast and nonblast-related mild traumatic brain injuries in Afghanistan and Iraq war veterans. J Int Neuropsychol Soc. Sep. 2010;16(5):856-866. [pmid: 20682086].
29 Nelson WN, Hoelzle JB, Doane BM, et al. Neuropsychological Outcomes of U.S. Veterans with Report of Remote Blast-Related Concussion and Current Psychopathology. J Int Neuropsychol Soc. 2012;18:1-11. [pmid: 22152338].
30 Nelson NW, Hoelzle JB, McGuire KA, Ferrier-Auerbach AG, Charlesworth MJ, Sponheim SR. Evaluation context impacts neuropsychological performance of OEF/OIF veterans with reported combat-related concussion. Arch Clin Neuropsychol. Dec. 2010;25(8):713-723. [pmid: 20923860].
31 Patil VK, St Andre JR, Crisan E, et al. Prevalence and treatment of headaches in veterans with mild traumatic brain injury. Headache. Jul-Aug. 2011;51(7):1112-1121. [pmid: 21762135].
32 Ruff RL, Riechers RG 2nd, Wang XF, Piero T, Ruff SS. A case-control study examining whether neurological deficits and PTSD in combat veterans are related to episodes of mild TBI. BMJ Open. 2012;2(2):e000312.
33 Ruff RL, Ruff SS, Wang XF. Headaches among Operation Iraqi Freedom/Operation Enduring Freedom veterans with mild traumatic brain injury associated with exposures to explosions. J Rehabil Res Dev. 2008;45(7):941-952. [pmid: 19165684].
34 Ruff RL, Ruff SS, Wang XF. Improving sleep: initial headache treatment in OIF/OEF veterans with blast-induced mild traumatic brain injury. J Rehabil Res Dev. 2009;46(9):1071-1084. [pmid: 20437313].
35 Schiehser DM, Delis DC, Filoteo JV, et al. Are self-reported symptoms of executive dysfunction associated with objective executive function performance following mild to moderate traumatic brain injury?. J Clin Exp Neuropsychol. Jul. 2011;33(6):704-714. [pmid: 21958432].
36 Spencer RJ, Drag LL, Walker SJ, Bieliauskas LA. Self-reported cognitive symptoms following mild traumatic brain injury are poorly associated with neuropsychological performance in OIF/OEF veterans. J Rehabil Res Dev. 2010;47(6):521-530. [pmid: 20848365].
37 Swick D, Honzel N, Larsen J, Ashley V, Justus T. Impaired response inhibition in veterans with post-traumatic stress disorder and mild traumatic brain injury. J Int Neuropsychol Soc. Sep. 2012;18(5):917-926. [pmid: 22595028].
38 Theeler BJ, Erickson JC. Mild head trauma and chronic headaches in returning US soldiers. Headache. Apr. 2009;49(4):529-534. [pmid: 19220499].
39 Toblin RL, Riviere LA, Thomas JL, Adler AB, Kok BC, Hoge CW. Grief and physical health outcomes in U.S. soldiers returning from combat. J Affect Disord. Feb. 2012;136(3):469-475. [pmid: 22154707].
40 Wagner A, Jakupcak M. Combat-related stress reactions among U.S. veterans of wartime service. Matthews JHLMD, editor. The Oxford Handbook of Military Psychology. New York. Oxford University Press. 2012:15-28.
41 Carlson KF, Kehle SM, Meis LA, et al. Prevalence, assessment, and treatment of mild traumatic brain injury and posttraumatic stress disorder: a systematic review of the evidence. J Head Trauma Rehabil. Mar-Apr. 2011;26(2):103-115. [pmid: 20631631].
42 Cohen B, Gima K, Bertenthal D, Kim S, Marmar C, Seal K. Mental Health Diagnoses and Utilization of VA Non-Mental Health Medical Services Among Returning Iraq and Afghanistan Veterans. J Gen Intern Med. 2010;25(1):18-24. [pmid: 19787409].
43 Lew HL, Otis JD, Tun C, Kerns RD, Clark ME, Cifu DX. Prevalence of chronic pain, posttraumatic stress disorder, and persistent postconcussive symptoms in OIF/OEF veterans: polytrauma clinical triad. J Rehabil Res Dev. 2009;46(6):697-702. [pmid: 20104399].
44 Pietrzak RH, Johnson DC, Goldstein MB, Malley JC, Southwick SM. Posttraumatic stress disorder mediates the relationship between mild traumatic brain injury and health and psychosocial functioning in veterans of Operations Enduring Freedom and Iraqi Freedom. J Nerv Ment Dis. Oct. 2009;197(10):748-753. [pmid: 19829203].
45 Uomoto JM, Williams RM, Randa LA. Neurobehavioral consequences of combat-related blast injury and polytrauma. Ashley Mark J, editor. 2010:63-95.
46 Vasterling JJ, Bryant RA, Keane TM. Understanding the interface of traumatic stress and mild traumatic brain injury: Background and conceptual framework. Vasterling Jennifer J, editor. 2012:3-11.
47 Bogdanova Y, Verfaellie M. Cognitive sequelae of blast-induced traumatic brain injury: recovery and rehabilitation. Neuropsychol Rev. Mar. 2012;22(1):4-20. [pmid: 22350691].
48 Dolan S, Martindale S, Robinson J, et al. Neuropsychological sequelae of PTSD and TBI following war deployment among OEF/OIF veterans. Neuropsychol Rev. Mar. 2012;22(1):21-34. [pmid: 22350690].
49 APA. APA. Diagnostic and statistical manual of mental disorders. Revised 4th ed. Washington, DC. 2000.
50 Ruff R, Grant I. Postconcussional disorder: Background to DSM-IV and future considerations. Roberts NRVRJ, editor. Evaluation and treatment of mild traumatic brain injury. Mahwah. Lawrence Erlbaum Associates, Inc. 1999.
51 Brewin CR, Kleiner JS, Vasterling JJ, Field AP. Memory for emotionally neutral information in posttraumatic stress disorder: A meta-analytic investigation. Journal of Abnormal Psychology. Aug. 2007;116(3):448-463. [pmid: 17696700].
52 Leskin LP, White PM. Attentional networks reveal executive function deficits in posttraumatic stress disorder. Neuropsychology. May. 2007;21(3):275-284. [pmid: 17484590].
53 Vasterling JJ, Brailey K, Constans JI, Sutker PB. Attention and memory dysfunction in posttraumatic stress disorder. Neuropsychology. Jan. 1998;12(1):125-133. [pmid: 9460740].
54 Vasterling JJ, Proctor SP. Understanding the neuropsychological consequences of deployment stress: a public health framework. J Int Neuropsychol Soc. Jan. 2011;17(1):1-6. [pmid: 21083962].
55 High WMJ, Sander AM, Struchen MA, Hart KA. Rehabilitation for Traumatic Brain Injury. New York, NY. Oxford University Press. 2005.
56 Crooks CY, Zumsteg JM, Bell KR. Traumatic Brain Injury: A Review of Practice Management and Recent Advances. Physical medicine and rehabilitation clinics of North America. 2007;18(4):681-710. [pmid: 17967360].
57 McCrea M. Functional Outcome after mTBI. Series OW, editor. Mild Traumatic Brain Injury and Postconcussion Syndrome: The New Evidence Base for Diagnosis and Treatment. New York, NY. Oxford University Press. 2008.
58 Public Law -. Caregivers and Veterans Omnibus Health Services Act of 2010. United States Government Printing Office. 2010.
59 Carroll LJ, Cassidy JD, Peloso PM, et al. Prognosis for mild traumatic brain injury: results of the who collaborating centre task force on mild traumatic brain injury. J Rehabil Med. 2004;36(Supplement 43):84-105. [pmid: 15083873].
60 Belanger HG, Vanderploeg RD. The neuropsychological impact of sports-related concussion: a meta-analysis. J Int Neuropsychol Soc. Jul. 2005;11(4):345-357. [pmid: 16209414].
61 Dikmen SS, Corrigan JD, Levin HS, Machamer J, Stiers W, Weisskopf MG. Cognitive outcome following traumatic brain injury. J Head Trauma Rehabil. Nov-Dec. 2009;24(6):430-438. [pmid: 19940676].
62 Pertab JL, James KM, Bigler ED. Limitations of mild traumatic brain injury meta-analyses. Brain Inj. 2009;23(6):498-508. [pmid: 19484623].
63 Metting Z, Wilczak N, Rodiger LA, Schaaf JM, van der Naalt J. GFAP and S100B in the acute phase of mild traumatic brain injury. Neurology. May. 1. 2012;78(18):1428-1433. [pmid: 22517109].
64 Sharma R, Laskowitz DT. Biomarkers in traumatic brain injury. Curr Neurol Neurosci Rep. Oct. 2012;12(5):560-569. [pmid: 22811071].
65 Jeter CB, Hergenroeder GW, Hylin MJ, Redell JB, Moore AN, Dash PK. Biomarkers for the diagnosis and prognosis of mild traumatic brain injury/concussion. J Neurotrauma. 2012. Oct. 12. (Epub ahead of print).
66 Goldstein LE, Fisher AM, Tagge CA. Chronic traumatic encephalopathy in blast-exposed military veterans and a blast neurotrauma mouse model. Sci Transl Med. 2012;4(134):134ra160.
67 Omalu BI, Bailes J, Hammers JL, Fitzsimmons RP. Chronic Traumatic Encephalopathy, Suicides and Parasuicides in Professional American Athletes: The Role of the Forensic Pathologist. American Journal of Forensic Medicine & Pathology June. 2010;31(2):130-132.
68 Baugh CM, Stamm JM, Riley DO, et al. Chronic traumatic encephalopathy: neurodegeneration following repetitive concussive and subconcussive brain trauma. Brain imaging behav. Jun. 2012;6(2):244-254. [pmid: 22552850].
69 McDonald BC, Saykin AJ, McAllister TW. Functional MRI of mild traumatic brain injury (mTBI): progress and perspectives from the first decade of studies. Brain imaging behav. Jun. 2012;6(2):193-207. [pmid: 22618832].
70 Lin AP, Liao HJ, Merugumala SK, Prabhu SP, Meehan WP 3rd, Ross BD. Metabolic imaging of mild traumatic brain injury. Brain imaging behav. Jun. 2012;6(2):208-223. [pmid: 22684770].
71 Bigler ED, Maxwell WL. Neuropathology of mild traumatic brain injury: relationship to neuroimaging findings. Brain imaging behav. Jun. 2012;6(2):108-136. [pmid: 22434552].
72 Shenton M, Hamoda H, Schneiderman J, et al. A review of magnetic resonance imaging and diffusion tensor imaging findings in mild traumatic brain injury. Brain Imaging and Behavior. Jun. 2012;6(2):137-192. [pmid: 22438191].
73 Whittaker R, Kemp S, House A. Illness perceptions and outcome in mild head injury: a longitudinal study. J Neurol Neurosurg Psychiatry. 2007;78(6):644-646. [pmid: 17507448].
74 Wilde EA, Whiteneck GG, Bogner J, et al. Recommendations for the Use of Common Outcome Measures in Traumatic Brain Injury Research. Archives of physical medicine and rehabilitation. 2010;91(11):1650-1660.e1617. [pmid: 21044708].
75 Morissette SB, Woodward M, Kimbrel NA, et al. Deployment-related TBI, persistent postconcussive symptoms, PTSD, and depression in OEF/OIF veterans. Rehabil Psychol. Nov. 2011;56(4):340-350. [pmid: 22121940].