# METHODS

## TOPIC DEVELOPMENT

This project was nominated by Dr. Stuart Hoffman, Scientific Program Manager for the Brain Injury portfolio, Rehabilitation Research & Development Service. Operational partners include David X. Cifu, MD, Chair, VHA TBI Advisory Committee and National Director of Physical Medicine and Rehabilitation (PM&R) Program Office; Robert L. Ruff, MD, PhD, National Director for Neurology and Acting-Director of Rehabilitation Research and Development; Joel Scholten, MD, Associate Chief of Staff for Rehabilitation Services, Washington DC VA Medical Center Director of Special Projects, PM&R Program Office, Veterans Affairs Central Office (VACO); and Alexander Ommaya, DSc, Director of Translational Research, Office of Research and Development. We also received input from a technical expert panel.

Anticipated report usage:

The evidence synthesis review will be used by the VHA TBI Advisory Committee to develop strategies to determine which sub-groups are most at risk for long-term effects of mTBI. The review will be used to inform clinical practice and to identify how best to allocate future resources for effective screening for late complications of mTBI. The review will also identify gaps in evidence that warrant further research.

The final key questions are:

Key Question #1. For Veteran/military populations, what is the prevalence of health problems (such as pain, seizure disorders, headaches, migraines, and vertigo), cognitive deficits, functional limitations (such as employment status, changes in marital status/family dynamics), and mental health symptoms (such as PTSD and depression) that develop or persist following mTBI?

Key Question #2. What factors affect outcomes for Veteran/military patients with mTBI? Key Question 2A: For Veteran/military populations, are there pre-injury (premorbid) risk/protective factors (e.g., pre-injury mental health factors, genetic factors, or prior concussions) that affect outcomes for mTBI? Key Question 2B: For Veteran/military populations, are there post-injury risk/protective factors (e.g., PTSD) that affect outcomes for mTBI?

Key Question #3. What is the resource utilization over time for Veteran/military patients with mTBI?

## SEARCH STRATEGY

We searched Medline, PsychINFO and Cochrane Register of Controlled Trials (OVID) for observational studies, clinical trials, systematic reviews, and cost studies, from database inception to October 3^rd^, 2012. We limited the search to articles involving human subjects and published in the English language. We adapted the search strategy developed by the WHO Collaborating Centre for Neurotrauma Prevention, Management and Rehabilitation Task Force for a recent systematic review of prognosis after mTBI, which included the terms ‘traumatic brain injury,’ ‘craniocerebral trauma,’ ‘prognosis,’ and ‘recovery of function.’4 The full details of the search strategy are provided in Appendix A. The preliminary WHO Collaborating Centre for Neurotrauma Prevention, Management and Rehabilitation Task Force search strategy was reviewed by a library scientist and by our team of investigators with clinical expertise in order to assure comprehensiveness of the search. The search was expanded to include additional mTBI search terminology following the discovery of a relevant article which was not identified in the preliminary search. After review, we expanded the WHO Collaborating Centre for Neurotrauma Prevention, Management and Rehabilitation Task Force search with additional TBI terms and also limited the search to Veteran/military population studies by using terms including military, VA, and Veteran (Appendix A). We obtained additional articles from systematic reviews, reference lists of pertinent studies, reviews, editorials, and by consulting clinical and research experts. All citations were imported into an electronic database (EndNote X4).

## STUDY SELECTION

We included studies reporting outcomes in Veterans or military personnel who had suffered an mTBI using a case definition consistent with definitions in the VA/DoD Clinical Practice Guideline for Management of Concussion/Mild Traumatic Brain Injury. Abstracts of citations identified from literature searches were reviewed by the PI to assess for relevance to the key questions; a portion of the abstracts were dual reviewed by at least one additional member of the team to assure accuracy and consistency of coding. Full-text articles of potentially relevant abstracts were retrieved for further review, and reviewed by the PI and at least one additional reviewer. Full-text articles for which there was disagreement by two reviewers were reviewed by the team of investigators and included or excluded based on team consensus. Each article was reviewed using the eligibility criteria in Appendix B. A list of excluded studies grouped by reason for exclusion is reported in Appendix F. Eligible articles had English-language abstracts and provided data relevant to the key questions. Articles also had to report outcomes for members of the U.S. armed forces or Veterans.

Diagnostically, to have sustained a TBI one must have experienced an event (e.g., motor vehicle crash, fall) which resulted in a structural injury to the brain or a physiological disruption of brain function (e.g., alteration of consciousness,5 loss of consciousness [LOC], or post-traumatic amnesia6). TBI severity is classified according to the extent of harm to the brain or altered consciousness associated with the injury. Severity of residual symptoms reported or observed should not be used to classify TBI severity. Therefore, to apply consistent criteria to define mTBI and compare similar populations with mTBI, all included studies had to use a definition of mTBI consistent with the VA/Department of Defense (DoD) Clinical Practice Guideline for Management of Concussion/Mild Traumatic Brain Injury described in Appendix C. Articles that described their populations as having mTBI but used definitions of mTBI differing from the VA/DoD criteria were excluded from this evidence synthesis but are described in Appendix D. Due to the frequent lack of reporting or obtaining imaging results (e.g., MRI, CT scan), the only variation from this definition in included studies relates to positive imaging results: we included studies regardless of whether they reported or included participants with positive imaging results as long as the rest of their mTBI inclusion criteria were consistent with the VA/DoD criteria. Finally, we did not limit study eligibility based on number of mTBI incidents or the presence of comorbid conditions.

We published our key questions and abstract online so that they were available for public review. A summary of article inclusion criteria is as follows:

Population(s): Veterans or members of the military who have experienced mTBI. Studies that do not differentiate between adult and child populations, or between Veteran/military and civilian populations, will be excluded. Studies must state a clear case definition for mTBI that falls within the definitions provided by the VA/DoD Clinical Practice Guideline for Management of Concussion/Mild Traumatic Brain Injury (Appendix C).

Intervention(s): Not applicable to the proposed key questions.

Comparator(s): Similar populations that have not been diagnosed with mTBI or concussion; comparison group not required for inclusion.

Outcome(s): Health problems (e.g., pain, seizure disorders, chronic headaches, migraines, vertigo, etc.), cognitive deficits, functional limitations (e.g., employment status, marital status changes/family dynamic changes), mental health symptoms (e.g., diagnosis of PTSD or depression), and cost/resource utilization (ER visits, hospitalizations, outpatient appointments). Outcomes diagnosed post-mortem will be included (e.g., Chronic Traumatic Encephalopathy [CTE]).

Timing: No limitations based on time since injury.

Setting: No limitations based on study setting.

Study design: Systematic reviews, meta-analyses, randomized controlled trials, prospective and retrospective cohort studies, case control studies, case series, and cross-sectional studies.

Sample size: All included studies must include a minimum of 30 mTBI cases, so that a better level of precision and confidence in the results can be achieved.

## DATA ABSTRACTION

We abstracted the following data for each included study: sample selection, population characteristics, subject eligibility and exclusion criteria, number of subjects, comparison(s), and outcome(s) (See Table 1 and Appendix E). Data was abstracted by one investigator and reviewed for accuracy by at least one additional investigator.

## QUALITY ASSESSMENT

We assessed the quality of included studies pertaining to all of the key questions. We found no randomized trials meeting inclusion criteria, and our entire sample of included studies is comprised of observational studies of various designs, primarily retrospective cohort, case control, and case series. Issues of quality, particularly in observational studies, are often unique to the condition and outcomes of interest. Therefore, though we assessed quality using criteria based on the Newcastle-Ottawa quality assessment tools for observational studies7 the criteria that specifically related to this body of literature included the following: accurate definition of condition of interest, consecutive sample selection, use of validated assessment tools, blinding of outcome assessors, blinding of patients and assessors to study hypotheses, adjustment for known confounders including mental health condition, comparability of controls, response rate, attrition, and reduced risk of reporting bias. These indicators of study quality and potential for bias were abstracted by one investigator and reviewed for accuracy by at least one additional investigator who was not blinded to the original assessment. In cases of disagreement, the team of investigators reviewed the study and came to consensus on quality assessment. In addition to quality rating of individual studies, we evaluated the overall quality of the evidence for each key question as proposed by the GRADE Working Group.8

## DATA SYNTHESIS

We constructed evidence tables showing the study characteristics and results for all included studies organized by outcome. We critically analyzed studies to compare their characteristics, methods, and findings. We compiled a summary of findings for each outcome category and key question, and drew conclusions based on qualitative synthesis of the findings. We did not combine the studies in a quantitative manner via meta-analysis because of the heterogeneity of outcomes and study characteristics. The synthesis was conducted by the principal investigator, though all results were reviewed with the team of investigators to review and obtain consensus on the reported findings.

## RATING THE BODY OF EVIDENCE

We assessed the overall quality of evidence for outcomes using a method developed by the GRADE Working Group,8 which classified the grade of evidence across outcomes according to the following criteria:

- High = Further research is very unlikely to change our confidence on the estimate of effect.
- Moderate = Further research is likely to have an important impact on our confidence in the estimate of effect and may change the estimate.
- Low = Further research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate.
- Very Low = Any estimate of effect is very uncertain.

## PEER REVIEW

A draft version of this report was reviewed by 11 technical experts as well as clinical leadership. Their comments and our responses are presented in Appendix G.