# LIST OF EXCLUDED STUDIES GROUPED BY REASON FOR EXCLUSION

Population does not meet criteria for adult, human subjects who are Veterans or members of the military from any country

Publication contains no primary data and is not a systematic review of primary studies

Does not distinguish mild TBI from moderate or severe

Sample includes fewer than 30 mTBI cases

Does not report outcomes that address key questions

Does not meet VA DoD definition for mTBI