# RESULTS OF INCLUDED STUDIES

## Cognitive Functioning

Table 1a Language abilities and general fund of verbal knowledge measures in studies of U.S. Veterans and members of the U.S. military with mild TBI

Table 1b Visuospatial function in studies of U.S. Veterans and members of the U.S. military with mild TBI

Table 1c Memory functioning in studies of U.S. Veterans and members of the U.S. military with mild TBI

Table 1d Attention/concentration measures in studies of U.S. Veterans and members of the U.S. military with mTBI

Table 1e Cognitive processing speed in studies of U.S. Veterans and members of the U.S. military with mild TBI

Table 1f Executive functioning in studies of U.S. Veterans and members of the U.S. military with mild TBI

Table 1g Effort and motivation measures in a study of U.S. Veterans with mild TBI evaluated in a research versus forensic context

Table 1h Total and cross-domain composite scores in studies of U.S. Veterans and members of the U.S. military with mild TBI

Table 1i Self-reported cognitive deficits in studies of U.S. Veterans and members of the U.S. military with mild TBI

## Physical Health Outcomes

Table 2a Headache outcomes in studies of U.S. Veterans and members of the U.S. military with mild TBI

Table 2b Pain outcomes in studies of U.S. Veterans and members of the U.S. military with mild TBI

Table 2c Vestibular outcomes in studies of U.S. Veterans and members of the U.S. military with mild TBI

Table 2d Vision outcomes in studies of U.S. Veterans and members of the U.S. military with mild TBI

Table 2e Hearing outcomes in studies of U.S. Veterans and members of the U.S. military with mild TBI

Table 2f Neurological outcomes in studies of U.S. Veterans and members of the U.S. military with mild TBI

Table 2g Nausea/appetite outcomes in studies of U.S. Veterans and members of the U.S. military with mild TBI

## Mental Health Outcomes

Table 3a PTSD outcomes in studies of U.S. Veterans and members of the U.S. military with mild TBI

Table 3b Measures of anxiety in studies of U.S. Veterans and members of the U.S. military with mild TBI

Table 3c Measures of depression in studies of U.S. Veterans and members of the U.S. military with mild TBI

Table 3d Substance use disorders in studies of U.S. Veterans and members of the U.S. military with mild TBI

Table 3e Suicide-related outcomes in studies of U.S. Veterans and members of the U.S. military with mild TBI

Table 3f Other mental health outcomes in studies of U.S. Veterans and members of the U.S. military with mild TBI

## Functional/Social Outcomes

Table 4a Employment outcomes in studies of U.S. Veterans and members of the U.S. military with mild TBI

Table 4b Sleep outcomes in studies of U.S. Veterans and members of the U.S. military with mild TBI

Table 4c Social outcomes in studies of U.S. Veterans and members of the U.S. military with mild TBI

## Service Utilization/Costs

Table 5 Service utilization outcomes in studies of U.S. Veterans and members of the U.S. military with mild TBI