# EXCLUDED STUDIES THAT DID NOT MEET MTBI DEFINITION CRITERIA

Author, Year | Definition | Patients with Abnormal Imaging | Citation | How Assessed
Adams, Larson, Corrigan, et al., 2012^1^ | Length of LOC classified as < 1 minute, 1-20 minutes, or > 20 minutes. Used the Health Related Behaviors Among Active Duty Military Personnel Survey response categories: “The HRB Survey symptom response groups permit recoding LOC as up to 20 minutes and greater than 20 minutes. This provides insufficient information to code LOC using the American Congress of Rehabilitation Medicine's definition of mild TBI.” | NR | Kay, Harrington, Adams, et al., 1993 | Self-report survey
Arbisi, Polusny, Erbes, et al., 2011^2^ | Adapted from the Defense and Veterans Brain Injury Center screening tool: yes to last item “dazed, confused, see stars, get knocked out or lose consciousness” classified as mTBI. No participants reported “receiving treatment while in Iraq for a TBI or were removed from assigned duties as a result of exposure to blast or other form of head trauma.” | NR | Schwab et al., 2007 | Self-report mailed questionnaire
Armistead-Jehle, 2010^3^ | “Screened positive on the VHA TBI screens” for “possible mTBI.” “All patients suffered at most a mild TBI…, as none reported loss of consciousness of more than 30 minutes or posttraumatic amnesia of 24 hours or more.” | NR | US Department of Veterans Affairs, 2007 | Self-report
Bazarian, Donnelly, Peterson, et al., 2012^4^ | “Mild TBI diagnosis was determined by in-person interview using a 22-item questionnaire developed to establish the nature, probability, and severity of deployment-related TBI among OEF/OIF veterans. The interview followed previously published TBI diagnostic criteria, which include confirmation of a possible TBI event, confirmation of alteration of consciousness, and confirmation of postconcussion symptoms. On the basis of the standardized clinical interview, interviewers rated the likelihood of mild TBI according to a 6-point scale: “not at all likely,” “very unlikely,” “somewhat unlikely,” “somewhat likely,” “very likely,” and “almost certainly.” These likelihood categories were used in all analyses. However, for descriptive purposes, subjects were defined as having mild TBI if interviewers rated them “very likely” or “almost certainly.”” | NR | Lew, Poole, & Vanderploeg, 2007 | Clinical interview
Booth-Kewley, Highfill-McRoy, Larson, et al., 2012^5^ | “Mild TBI symptoms were assessed using a set of questions that asked participants whether they had received an injury to the head during their most recent deployment that involved ‘being dazed, confused, or ‘seeing stars'' or ‘not remembering the injury, or losing consciousness (knocked out).' A participant was classified as having a positive TBI screen if any of the three questions elicited a positive response.” | NR | Centers for Disease Control and Prevention & World Health Organization definitions adapted by the Defense and Veterans Brain Injury Center working group for military use | Self-report survey
Brenner, Terrio, Homaifar, et al., 2010^6^ | Warrior Administered Retrospective Casualty Assessment Tool (WARCAT) and Brief Trauma Brain Injury Screen. “All 45 participants whose test scores were included in analyses had a history of blast exposure with alteration of or loss of consciousness (LOC).” “The nature of the most serious mTBIs reported were: n = 30, altered consciousness only; n = 12, up to 1-min LOC; and n = 3, one to 20-min LOC.” | NR | Soldier Readiness Process, 2007; Schwab et al., 2007 | Chart review, self-report survey, and clinical interview
Brenner, Ivins, Schwab, Warden, Nelson, Jaffee, & Terrio, 2010^7^ | As described in Terrio et al., 2009: Warrior Administered Retrospective Casualty Assessment Tool (WARCAT) and Brief Trauma Brain Injury Screen | NR | Soldier Readiness Process, 2007; Schwab et al., 2007 | Chart review, self-report survey, and clinical interview
Cameron, Marshall, Sturdivant, & Lincoln, 2011^8^ | “Incident cases of mTBI were operationally defined according to the administrative case definition proposed by the Centers for Disease Control and Prevention (CDC) for research purposes… and include ICD-9-CM codes for skull fracture (800.00, 800.5, 801.0, 801.5, 803.0, 803.5, 804.0, and 804.5), concussion (850.0, 850.1, 850.5, and 850.9), intracranial injury of unspecified nature (854.0), and head injury unspecified (959.01). In addition to the four digit codes listed, all subordinate five-digit codes were also included.” | NR | Centers for Disease Control and Prevention, 2003 | Chart review
Carlson, Kehle, Meis, et al., 2011^9^ | “Included studies must have assessed participants for a “probable” TBI (identified using self-report screening instruments) or diagnosed TBI history.” | NR | NR | NA
Clement & Kennedy, 2003^10^ | LOC<60 minutes with no neurological findings | Excluded | NR | Chart review
Dougherty, MacGregor, Han, et al., 2011^11^ | International Classification of Diseases, 9^th^ Revision (ICD-9) codes 800.0-801.9, 803.0-804.9, 850.0-854.1. “The Abbreviated Injury Scale (AIS) was used to describe the severity of brain injury… Due to a small number of TBI observations with scores of 4 (severe injury) and 5 (critical injury) in the present study, TBI severity was classified as follows: 0 = No TBI, 1 = minor, 2 = moderate and 3-5 = serious to critical. Service members with AIS scores of 6 were not eligible for inclusion in the study.” | NR | Gennarelli & Wodzin, 2005 | Chart review
Drake, Gray, Yoder, et al., 2000^12^ | “Subjects were consecutive MTBI patients… meeting specific inclusion criteria… a documented TBI classified by accepted criteria as a mild TBI.” No specific mTBI definition noted. | NR | NR | Self-report and chart review
Eskridge, 2011^13^ | “Clinical diagnosis codes from the International Classification of Diseases, 9^th^ Revision (ICD-9) were assigned to each injury… In addition to the assigning of diagnosis codes, severity of each injury is accessed with two different standardized measures of injury severity; the Abbreviated Injury Scale (AIS) and the Injury Severity Scale (ISS)… The ISS for each blast episode was documented and categorized into one of four severity levels; mild (ISS 1-3), moderate (ISS 4-8), serious (ISS 9-15) and severe (ISS 16 and higher).” | NR | NR | Chart review
Fear, Jones, Groom, et al., 2009^14^ | “Criteria for identification include confusion or disorientation, loss of consciousness lasting less than 30 min or post-traumatic amnesia lasting less than 24 h.” However, description of population studied only states, “we have examined the prevalence of symptoms thought to be a consequence of mTBI,” with unclear description of how mTBI was determined. | NR | Holm, et al., 2005 | Chart review
Ferrier-Auerbach, Erbes, Polusny, et al., 2009^15^ | “Three items adapted from the Defense and Veterans Brain Injury Center (DVBIC) Blast Exposure Screening Questionnaire… (1) Were you ever so close to a blast that you could feel the blast wave (such as heat or pressure) or afterward had trouble hearing or problems with attention or memory?… (2) Did you have any injuries from a blast, vehicle crash, bullet/shrapnel or fall?… (3) Did any injury cause you to be dazed/confused, ‘see stars,’ get knocked out, or lose consciousness?” | NR | Schwab et al., 2007 | Self-report survey
French, Lange, Iverson, Ivins, et al., 2012^16^ | LOC < 15 mins; PTA < 24 hours; absence of intracranial abnormality on computed tomography or magnetic resonance imaging scan | Excluded | Used VA/DoD criteria, but data limited to LOC < 15 minute categories. | Chart review
Gottshall, Gray, Drake, et al., 2007^17^ | Definition: GCS 13-15. One patient identified as having an open head injury. LOC categorized as 31-60 (1 patient), and > 60 minutes (one patient), and up to 20 minutes (all remaining patients). | NR | American Academy of Neurology, 1997 | Clinical presentation (to ED or Battalion Aid Station)
Helfer, Jordan, Lee, et al., 2011^18^ | ICD-9CM codes 850.0, 850.11, 850.12, 850.2, 850.3, 850.4, 850.5, 850.9, 959.01, V15.52 | NR | US Dept of Health and Human Services, 2008 | Chart review
Heltemes, Dougherty, MacGregor, & Galarneau, 2011^19^ | International Classification of Diseases, 9^th^ Revision, Clinical Modification (ICD-9-CM) codes 800.0-801.9, 803.0-804.9, 850.0-854.1. | NR | Centers for Disease Control and Prevention, 2003 | Chart review
Hoffer, Balaban, Gottshall, et al., 2010^20^ | “Definitive diagnosis of mild traumatic brain as defined by the 2007 Joint Service Surgeon General's Definition” | NR | Assistant Secretary of Defense: Memorandum on Traumatic Brain Injury: Definition and Reporting. Available at http://www.pdhealth.mil/TBI.asp | In theater clinical evaluation
Hoffer, Donaldson, Gottshall, et al., 2009^21^ | No specific mTBI definition listed. | NR | NR | Clinical interview
Hoge, McGurk, Thomas, et al., 2008^22^ | Positive response to three questions: LOC, being dazed and confused, seeing stars or not remembering the injury. However, “four Soldiers reported LOC lasting longer than 30 minutes. Although technically they were considered to have a moderate TBI they were not excluded because the number was low and it was not possible to verify the self-report data on any of the subjects”. | NR | DVBIC, 2006; CDC, 2003 | Self-report
Ivins, Schwab, Baker, & Warden, 2003^23^ | “Head injury for which any LOC or any alteration of mental state without LOC was reported.” Reports rates of concussion grades separately, though the categories are divided by LOC < 20 minutes and LOC between 20-59 minutes. | NR | Kay et al., 1993 | Chart review
Ivins, Schwab, Baker, & Warden, 2006^24^ | ICD-9CM codes 800.00-801.99, 803.00-804.99, and 850.0-854.19 and AIS severity codes of minor or moderate. | NR | Kay et al., 1993; Thurman & Guerrero, 1999 | Chart review
Ivins, Kane, & Schwab, 2009^25^ | Brief Traumatic Brain Injury Screen (BTBIS); LOC criteria < 20 mins. Additional computerized survey administered; however, it appears that only those with LOC < 20 minutes were included in the further assessment. Brief Traumatic Brain Injury Screen (BTBIS); Patients who screened positive for TBI and had LOC< = 20 minutes and/or possible PTA< = 24 hours were identified as having MTBI with LOC or possible PTA | NR | Kay et al., 1993; Thurman & Guerrero, 1999 | Chart review
Ivins, 2010^26^ | Mapped ICD-9 CM diagnoses to the Abbreviated Injury Scale (AIS): ICD-9CM codes 800.00-801.99, 803.00-804.99, and 850.0-854.19 and AIS severity codes of minor or moderate. Combines mild and moderate into one category. | NR | Kay et al., 1993; Thurman & Guerrero, 1999 | Chart review
Lange, Pancholi, Bhagwat, et al., 2012^27^ | “PTA < 24 hours and LOC < 15 minutes.” “It was our preference to use a LOC criterion of < 30 minutes, consistent with commonly used diagnostic criteria… However, the available information regarding LOC was limited to categorical data that did not allow us to differentiate between LOC greater or lower than 30 min.” | Included | Carroll et al., 2004; Management of Concussion/mTBI Working Group, 2009; ACRM, 1993 | Chart review
Lange, Pancholi, Brickell, et al., 2012^28^ | LOC < 15 mins; PTA < 24 hours | Included | Used VA/DoD criteria, but data limited to LOC < 15 minute categories. | Chart review and clinical interview
Lange, Brickell, French, et al., 2012^29^ | Uncomplicated: PTA<24 hours, LOC < 15 mins, negative imaging; complicated: positive imaging. “It was our preference to use an LOC criterion of 30 min to classify MTBI consistent with commonly used military and civilian diagnostic criteria. However, the available information regarding LOC was limited to categorical data that did not allow us to differentiate between LOC greater or less than 30 min (i.e., available data = LOC < 15 min and LOC 16–60 min).” | Excluded | Used VA/DoD criteria, but data limited to LOC < 15 minute categories. | Routine comprehensive clinical evaluation
Lew, Garvert, Pogoda, et al., 2009^30^ | Mild TBI was defined as an initial GCS score of 13 to 15, PTA duration of <1 day, or LOC duration of <1 hour | NR | NR | Chart review and clinical evaluation
Luis, Venderploeg, & Curtiss, 2003^31^ | “During the interview, participants were asked, among many others, the following three questions: 1) since your discharge from active duty, have you been injured in a MVA? 2) Since your discharge from active duty have you injured your head (HI)? and (3) Did you lose consciousness as a result of the head injury?” Analysis by LOC group but time of LOC not specified. | NR | NR | Self-report
MacGregor, 2007^32^ | “An ICD-9 code in the following ranges was defined as a TBI (n = 124): 800.0-801.9 (fractures of the vault or base of the skull); 803.0-804.9 (other and unqualified and multiple fractures of the skull); and 850.0-854.1 (intracranial injury, including concussion, contusion, laceration, and hemorrhage)… Severity of TBI was indicated with the Abbreviated Injury Scale (AIS). The AIS ranges from 1 (relatively minor) to 6 (currently untreatable), and is determined separately for each different body region. Severity of TBI was determined by maximum AIS score for the head region – head AIS 1-2 indicated mild TBI, head AIS 3-5 indicated moderate-severe TBI. A majority of TBI identified via CHAMPS did not have a head AIS score present; in this case the TBI was assumed to be of mild severity due to a closed head injury.” | NR | ICD-9-CM, 2005 | Chart review
MacGregor, Dougherty, & Galarneau, 2011^33^ | International Classification of Diseases, 9^th^ Revision (ICD-9) codes 800.0-801.9, 803.0-804.9, 850.0-854.1. “The AIS was used to describe the severity of these injuries and the injuries were scored according to the following scale: 0, no injury; 1 minor; 2, moderate; 3, serious; 4, severe; 5, critical; 6, fatal injury. As per previous literature, each participant was categorized by the severity of their highest (or maximum) AIS Head score as mild (AIS score = 1-2), moderate (AIS score = 3), or severe (AIS score = 4-6). | NR | Ommaya, Ommaya, Dannenberg, et al., 1996 | Chart review
MacGregor, Dougherty, Morrison, et al., 2011^34^ | “A concussion was defined by the ICD-9-CM code of 850.0-850.9. Severity of concussion was defined using the AIS.” | NR | NR | Chart review
MacGregor, Shaffer, Dougherty, et al. 2010^35^ | ICD-9 codes 800-801.9, 803-804.9, and 850-854.1; Abbreviated Injury Scale (AIS) score 1-2 = “mild,” 3-5 = “moderate to severe” | NR | Ommaya et al., 1996 | Chart review
McGuire, Marsh, Sowin, & Robinson, 2012^36^ | “LOC less than 30 min or amnesia less than 60 min” | NR | Annegers et al., 1998 | NR
Mora, Ritenour, Wade, et al., 2009^37^ | “Consciousness status to determine mTBI was queried using both codes from ICD and Abbreviated Injury Scale for indications of trauma to the head, concussive injuries, and indications of consciousness at the time of injury. A loss of consciousness served as the definition for mTBI. | NR | NR | Chart review
Morgan, Lockwood, Steinke, et al., 2012^38^ | No clear mTBI definition. | NR | NR | Self-report screening and clinical interview
Nelson, Weiser, Giford, et al., 2011^39^ | “The Brief Traumatic Brain Injury Screen was used to identify cases (probable mTBl) and controls (no mTBI). Individuals were placed in the “probable mTBl” group if they endorsed an injury (reported at least one injury on the BTBIS) and indicated that they had lost consciousness for a defined period of time (ranging from less than 1 minute to longer than 20 minutes) following the injury. Those who did not report an injury or a loss of consciousness (LOC) for any amount of time following an injury acted as the control group.” | NR | Defense and Veterans Brain Injury Center (DVBIC) | Chart review
Olson-Madden, Forster, Huggins, & Schneider, 2012^40^ | “Injury severity data were coded as either mild (alteration in consciousness or loss of consciousness </ = 30 minutes) or moderate/severe (loss of consciousness > 30 minutes).” | NR | Kay et al., 1993 | Clinical interview
Ommaya, Ommaya, Dannenberg, et al., 1996^41^ | “Head-injury-related discharge diagnosis (800.00-801.99, 803.00-804.99, and 850.0-854.19).” Injury Severity Scale and Abbreviated Injury Scale were calculated. | NR | NR | Chart review
Ommaya, Salazar, Dannenberg, et al., 1996^42^ | “Records with a head-injury hospital-related discharge diagnosis (800.00-801.99, 803.00-804.99, and 850.0-854.19) were identified as described in a previous study.” “Maximum Abbreviated Injury Score (AIS) head and Injury Severity Score (ISS) were computed using the ICD-9 map. Mild TBI was defined as maximum AIS head equal to 1 or 2” | NR | NR | Clinical records
Pietrzak, Johnson, Goldstein, Malley, Southwick 2009^43^ | “Positive mTBI screen” based on endorsement of all 4 items on the DVBIC questionnaire | NR | GAO, 2008 & DVBIC, 2006 | Self-report survey
Plassman, Havlik, Steffens, et al., 2000^44^ | “1) mild injury = loss of consciousness or posttraumatic amnesia for less than 30 minutes, with no skull fracture; 2) moderate injury = loss of consciousness or post-traumatic amnesia for more than 30 minutes but less than 24 hours, and/or a skull fracture; and 3) severe injury = loss of consciousness or post-traumatic amnesia for more than 24 hours.” | NR | Frankowski, Annengers, & Whitman, 1985 | Chart review
Polusny, Kehle, Nelson, Erbes, Arbisi, Thuras, 2011^45^ | Injury with altered mental status or LOC (items 1-3 on DVBIC screen) | NR | Schwab et al., 2007 | Self-report in theater, 1 month prior to return home
Roebuck-Spencer, Vincent, Twille, et al., 2012^46^ | “Although data on recency and severity of injury were not available in this dataset, TBIs reported in this study are presumed to be mild in nature given that Service Members were still on active duty. Mild TBI was defined as such when individuals reported an injury event accompanied by an alteration of consciousness. This included endorsement of at least one of the following: feeling dazed or confused, experiencing loss of consciousness (LOC), or experiencing loss of memory for the injury or posttraumatic amnesia (PTA) for the event.” | NR | NR | Self-report screening tool
Romesser, Shen, Reblin, Kircher, Allen, Roberts, & Marchand, 2011^47^ | “History of military-related concussion during a VHA TBI secondary evaluation.” Excluded if “self-report suggested a history of a moderate or severe TBI (i.e., if they endorsed loss of consciousness more than 30 minutes).” | NR | NR | Clinical interview
Rona, Jones, Fear, et al., 2012^48^ | “Possible mTBI was assessed using a modified version of the BTBIS… A second item asked about possible symptoms associated with the injury. These were losing consciousness; being dazed or confused; not remembering the injury; concussion (e.g., headache, dizziness); head injury, and none of these. Participants were asked to tick all that applied. Self-report of the duration of any loss of consciousness was also obtained, we eliminated one participant from the analysis who reported prolonged loss of consciousness… Participants who endorsed at least one of these symptoms were classified as having mTBI.” | NR | Iverson, Langlois, McCrea, & Kelly, 2009 | Self-report questionnaire
Rona, Jones, Fear, et al., 2012^49^ | “Possible mTBI was assessed using a modified version of the BTBIS, which included an item exploring possible causes of injury (blast, shrapnel fragments, bullet, fall, and vehicle accident and other). Participants could state that they had not suffered an injury during deployment. A second item asked about possible symptoms associated with the injury. These were losing consciousness; being dazed or confused; not remembering the injury; concussion (e.g., headache, dizziness); head injury; and none of these. Participants were asked to tick all that applied. Self-report of the duration of any loss of consciousness was also obtained, we eliminated 1 participant from the analysis who reported prolonged loss of consciousness (which would be classified traumatic brain injury, not mTBI). Participants who endorsed at least one of these symptoms were classified as having mTBI.” | NR | Iverson, Langlois, McCrea, & Kelly, 2009 | Self-report questionnaire
Schneiderman, Braver & Kang, 2008^50^ | Three-item Brief Traumatic Brain Injury Screen | NR | Defense and Veterans Brain Injury Center | Self-report survey
Skopp, Trofimovich, Grimes, et al., 2012^51^ | mild TBI (subset of all TBI codes): 310.2, 800.00-800.02, 800.06, 800.09, 800.50, 800.52, 801.00, 801.01, 801.02, 801.06, 801.09, 801.50, 801.51, 801.52, 803.00-803.02, 803.06, 803.09, 803.50, 803.51, 803.52, 804.00, 804.01, 804.02, 804.06, 804.09, 804.50, 804.51, 804.52, 850.0, 805.1, 850.11, 850.9, 959.01, V15.52, V15.5_7, V15.5_C, V15.52_2, V15.52_2,V15.52_7, V15.52_C | NR | DoD standard TBI surveillance case definition to ascertain TBI status and severity | Chart review
Theeler, Flynn, & Erickson, 2010^52^ | “2-question screen followed by a 10-question screen… The first question asks if, while deployed, the soldier was exposed to or near a blast, improvised explosive device (IED) explosion, car bomb, suicide explosion, or exposed to any other combat event or resulted in a blow or jolt to the head. The second question asks if the soldier was involved in a motor vehicle accident, a fall, a sports accident, or any other event that caused a blow to the head or resulted in a neck whiplash. If the soldier answers yes to either question 1 or 2, 10 more questions asking about loss of consciousness, dazed sensation after the event, and neurologic or behavioral sequelae following the event are administered. This questionnaire is scored in a standardized manner from 0 to 39.The case definition for concussion constituted a score of 5 or greater on the 2-plus-10 questionnaire.” | NR | NR | Self-report survey
Theeler, Flynn, & Erickson, 2012^53^ | No specific criteria: 2-question followed by a 10-question screen if the soldier answers yes to either of the first 2 questions. This questionnaire is scored in a standardized manner from 0 to 39; the score from the 2-plus-10 questionnaire will herein be called the TBI Score | NR | Theeler, Flynn, & Erickson, 2010 | Self-report survey
Vanderploeg, Belanger, & Curtiss, 2009^54^ | “Have you injured your head?… Did you lose consciousness as a result of the head injury?” “those individuals who required hospitalization after their head injury (n = 40) were excluded.” “head injury with altered consciousness” were classified as mild TBI. | NR | NR | Clinical interview
Vanderploeg, Curtiss & Belanger, 2005^55^ | “During the interview, participants were asked, among many others, the following three questions: 1) Since your discharge from active duty, have you been injured in a MVA? 2) Since your discharge from active duty have you injured your head (HI)? and 3) Did you lose consciousness as a result of the head injury?” | NR | NR | Self-report
Vanderploeg, Curtiss, Duchnick, Luis, 2003^56^ | Positive responses to following questions: “Since discharge from active duty, have you been injured in a MVA?”; “Since discharge from active duty, have you injured your head (from any cause)?”; and “Did you lose consciousness as a result of the head injury?” | NR | NR | Self-report survey
Vasterling, Brailey, Proctor, et al., 2012^57^ | “Congruent with reports showing stronger associations between clinical outcomes and TBI following loss of consciousness v. altered consciousness, only those pre- to post-deployment interval injuries resulting in loss of consciousness were queried.” | NR | NR | Self-report survey
Wilk, Herrell, Wynn, Riviere, & Hoge, 2012^58^ | “Injury resulted in being dazed, confused, or seeing stars, not remembering the injury, or losing consciousness (knocked out).” | NR | DoD/VA Brain Injury Center Brief Traumatic Brain Injury Screen | Self-report survey
Wilk, Thomas, McGurk, et al., 2010^59^ | “Injury resulted in being dazed, confused, or seeing stars, not remembering the injury, or losing consciousness (knocked out).” | NR | DoD/VA Brain Injury Center Brief Traumatic Brain Injury Screen | Self-report survey
Yurkiewicz, Lappan, Neely, et al., 2012^60^ | “Defense and Veterans Brain Injury Center (DVBIC) assesses TBI severity after a blast event or motor vehicle accident, answers questions about evacuation and in-theater clinical care and medication, and provides recommendations on headache management and vision, hearing, vestibular, and neurologic issues. Successes of the program include a stratified headache protocol for primary care providers and an early management protocol for mild TBI and posttraumatic headache stratified headache protocol.” “We reviewed consults sent to the neurology group from October 2006 to December 2010 and consults sent to the TBI group from March 2008 to December 2010. Microsoft Excel spreadsheets were constructed to organize and analyze data regarding number of consultations, response times, location of origin, branch of service, clinical images transmitted, anatomic location of complaint, type of injury, workup recommended, and treatment and evacuation recommendations.” | NR | DVBIC Brief Traumatic Brain Injury Screen | Chart review

Note. None of the studies reported information on assessor blinding of study hypotheses when assessing mTBI.

## Bibliography of studies excluded for not meeting mTBI definition criteria

1 Adams RS, Larson MJ, Corrigan JD, Horgan CM, Williams TV. Frequent binge drinking after combat-acquired traumatic brain injury among active duty military personnel with a past year combat deployment. J Head Trauma Rehabil. Sep. 2012;27(5):349-360. [pmid: 22955100].
2 Arbisi PA, Polusny MA, Erbes CR, Thuras P, Reddy MK. The Minnesota Multiphasic Personality Inventory-2 Restructured Form in National Guard soldiers screening positive for posttraumatic stress disorder and mild traumatic brain injury. Psychol Assess. Mar. 2011;23(1):203-214. [pmid: 21381845].
3 Armistead-Jehle P. Symptom validity test performance in U.S. veterans referred for evaluation of mild TBI. Appl Neuropsychol. Jan. 2010;17(1):52-59. [pmid: 20146122].
4 Bazarian JJ, Zhu T, Blyth B, Borrino A, Zhong J. Subject-specific changes in brain white matter on diffusion tensor imaging after sports-related concussion. Magn Reson Imaging. Feb. 2012;30(2):171-180. [pmid: 22079073].
5 Booth-Kewley S, Highfill-McRoy RM, Larson GE, Garland CF, Gaskin TA. Anxiety and depression in marines sent to war in iraq and afghanistan. J Nerv Ment Dis. Sep. 2012;200(9):749-757. [pmid: 22922233].
6 Brenner LA, Terrio H, Homaifar BY, et al. Neuropsychological test performance in soldiers with blast-related mild TBI. Neuropsychology. Mar. 2010;24(2):160-167. [pmid: 20230110].
7 Brenner LA, Ivins BJ, Schwab K, et al. Traumatic brain injury, posttraumatic stress disorder, and postconcussive symptom reporting among troops returning from iraq. J Head Trauma Rehabil. Sep-Oct. 2010;25(5):307-312. [pmid: 20042982].
8 Cameron KL, Marshall SW, Sturdivant RX, Lincoln AE. Trends in the incidence of physician-diagnosed mild traumatic brain injury among active duty U.S. military personnel between 1997 and 2007. J Neurotrauma. May. 2012;29(7):1313-1321. [pmid: 22332633].
9 Carlson KF, Kehle SM, Meis LA, et al. Prevalence, assessment, and treatment of mild traumatic brain injury and posttraumatic stress disorder: a systematic review of the evidence. J Head Trauma Rehabil. Mar-Apr. 2011;26(2):103-115. [pmid: 20631631].
10 Clement PF, Kennedy JE. Wechsler Adult Intelligence Scale-third edition characteristics of a military traumatic brain injury sample. Mil Med. Dec. 2003;168(12):1025-1028. [pmid: 14719630].
11 Dougherty AL, MacGregor AJ, Han PP, Heltemes KJ, Galarneau MR. Visual dysfunction following blast-related traumatic brain injury from the battlefield. Brain Inj. 2011;25(1):8-13. [pmid: 21117919].
12 Drake AI, Gray N, Yoder S, Pramuka M, Llewellyn M. Factors predicting return to work following mild traumatic brain injury: A discriminant analysis. The Journal of Head Trauma Rehabilitation. Oct. 2000;15(5):1103-1112. [pmid: 10970931].
13 Eskridge SL. Combat-related blast injuries: Injury types and outcomes. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2012;72(7-B):3929.
14 Fear N, Jones E, Groom M, et al. Symptoms of post-concussional syndrome are nonspecifically related to mild traumatic brain injury in UK Armed Forces personnel on return from deployment in Iraq: An analysis of self-reported data. Psychological Medicine. Aug. 2009;39(8):1379-1387. [pmid: 18945380].
15 Ferrier-Auerbach AG, Erbes CR, Polusny MA, Rath CM, Sponheim SR. Predictors of emotional distress reported by soldiers in the combat zone. J Psychiatr Res. May. 2010;44(7):470-476. [pmid: 19939409].
16 French LM, Lange RT, Iverson GL, Ivins B, Marshall K, Schwab K. Influence of bodily injuries on symptom reporting following uncomplicated mild traumatic brain injury in US military service members. J Head Trauma Rehabil. Jan-Feb. 2012;27(1):63-74. [pmid: 21897286].
17 Gottshall KR, Gray NL, Drake AI, Tejidor R, Hoffer ME, McDonald EC. To investigate the influence of acute vestibular impairment following mild traumatic brain injury on subsequent ability to remain on activity duty 12 months later. Mil Med. Aug. 2007;172(8):852-857. [pmid: 17803077].
18 Helfer TM, Jordan NN, Lee RB, Pietrusiak P, Cave K, Schairer K. Noise-induced hearing injury and comorbidities among postdeployment U.S. Army soldiers: April 2003-June 2009. Am J Audiol. Jun. 2011;20(1):33-41. [pmid: 21474555].
19 Heltemes KJ, Dougherty AL, MacGregor AJ, Galarneau MR. Alcohol abuse disorders among U.S. service members with mild traumatic brain injury. Mil Med. Feb. 2011;176(2):147-150. [pmid: 21366075].
20 Hoffer ME, Balaban C, Gottshall K, Balough BJ, Maddox MR, Penta JR. Blast exposure: vestibular consequences and associated characteristics. Otol Neurotol. Feb. 2010;31(2):232-236. [pmid: 20009782].
21 Hoffer ME, Donaldson C, Gottshall KR, Balaban C, Balough BJ. Blunt and blast head trauma: different entities. Int Tinnitus J. 2009;15(2):115-118. [pmid: 20420334].
22 Hoge CW, McGurk D, Thomas JL, Cox AL, Engel CC, Castro CA. Mild traumatic brain injury in U.S. Soldiers returning from Iraq. N Engl J Med. Jan. 31. 2008;358(5):453-463. [pmid: 18234750].
23 Ivins BJ, Schwab KA, Warden D, et al. Traumatic brain injury in U.S. Army paratroopers: prevalence and character. J Trauma. Oct. 2003;55(4):617-621. [pmid: 14566111].
24 Ivins BJ, Schwab KA, Baker G, Warden DL. Hospital admissions associated with traumatic brain injury in the US Army during peacetime: 1990s trends. Neuroepidemiology. 2006;27(3):154-163. [pmid: 17035692].
25 Ivins BJ, Kane R, Schwab KA. Performance on the Automated Neuropsychological Assessment Metrics in a nonclinical sample of soldiers screened for mild TBI after returning from Iraq and Afghanistan: a descriptive analysis. J Head Trauma Rehabil. Jan-Feb. 2009;24(1):24-31. [pmid: 19158593].
26 Ivins BJ. Hospitalization associated with traumatic brain injury in the active duty US Army: 2000-2006. NeuroRehabilitation. 2010;26(3):199-212. [pmid: 20448310].
27 Lange RT, Pancholi S, Bhagwat A, Anderson-Barnes V, French LM. Influence of poor effort on neuropsychological test performance in U.S. military personnel following mild traumatic brain injury. J Clin Exp Neuropsychol. 2012;34(5):453-466. [pmid: 22273465].
28 Lange RT, Pancholi S, Brickell TA, et al. Neuropsychological Outcome from Blast versus Non-blast: Mild Traumatic Brain Injury in U.S. Military Service Members. J Int Neuropsychol Soc. May. 2012;18(3):595-605. [pmid: 22459022].
29 Lange RT, Brickell TA, French LM, et al. Neuropsychological Outcome from Uncomplicated Mild, Complicated Mild, and Moderate Traumatic Brain Injury in US Military Personnel. Arch Clin Neuropsychol. 2012;27(5):480-494. [pmid: 22766317].
30 Lew HL, Garvert DW, Pogoda TK, et al. Auditory and visual impairments in patients with blast-related traumatic brain injury: Effect of dual sensory impairment on Functional Independence Measure. J Rehabil Res Dev. 2009;46(6):819-826. [pmid: 20104405].
31 Luis CA, Vanderploeg RD, Curtiss G. Predictors of postconcussion symptom complex in community dwelling male veterans. J Int Neuropsychol Soc. Nov. 2003;9(7):1001-1015. [pmid: 14738282].
32 Macgregor AJ. Physical injury and psychological outcomes among United States combat veterans. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2007;68(6-B):3665.
33 MacGregor AJ, Dougherty AL, Galarneau MR. Injury-specific correlates of combat-related traumatic brain injury in Operation Iraqi Freedom. The Journal of Head Trauma Rehabilitation. Jul-Aug. 2011;26(4):312-318. [pmid: 20808241].
34 MacGregor AJ, Dougherty AL, Morrison RH, Quinn KH, Galarneau MR. Repeated concussion among U.S. military personnel during Operation Iraqi Freedom. J Rehabil Res Dev. 2011;48(10):1269-1278. [pmid: 22234670].
35 MacGregor AJ, Shaffer RA, Dougherty AL, et al. Prevalence and psychological correlates of traumatic brain injury in operation iraqi freedom. J Head Trauma Rehabil. Jan-Feb. 2010;25(1):1-8. [pmid: 20051901].
36 McGuire SA, Marsh RW, Sowin TW, Robinson AY. Aeromedical decision making and seizure risk after traumatic brain injury: longitudinal outcome. Aviat Space Environ Med. Feb. 2012;83(2):140-143. [pmid: 22303594].
37 Mora AG, Ritenour AE, Wade CE, Holcomb JB, Blackbourne LH, Gaylord KM. Posttraumatic stress disorder in combat casualties with burns sustaining primary blast and concussive injuries. J Trauma. Apr. 2009;66(4 Suppl):S178-185. [pmid: 19359963].
38 Morgan M, Lockwood A, Steinke D, Schleenbaker R, Botts S. Pharmacotherapy regimens among patients with posttraumatic stress disorder and mild traumatic brain injury. Psychiatric Services. Feb. 2012;63(2):182-185. [pmid: 22302339].
39 Nelson C St, Weiser M, Gifford S, Gallimore J, Morningstar A. Knowledge gained from the Traumatic Brain Injury Screen-Implications for treating Canadian military personnel. Mil Med. Feb. 2011;176(2):156-160. [pmid: 21366077].
40 Olson-Madden JH, Forster JE, Huggins J, Schneider A. Psychiatric diagnoses, mental health utilization, high-risk behaviors, and self-directed violence among veterans with comorbid history of traumatic brain injury and substance use disorders. J Head Trauma Rehabil. Sep. 2012;27(5):370-378. [pmid: 22955102].
41 Ommaya AK, Ommaya AK, Dannenberg AL, Salazar AM. Causation, incidence, and costs of traumatic brain injury in the U.S. military medical system. J Trauma. Feb. 1996;40(2):211-217. [pmid: 8637068].
42 Ommaya AK, Salazar AM, Dannenberg AL, Chervinsky AB, Schwab K. Outcome after traumatic brain injury in the U.S. military medical system. J Trauma. Dec. 1996;41(6):972-975. [pmid: 8970548].
43 Pietrzak RH, Johnson DC, Goldstein MB, Malley JC, Southwick SM. Posttraumatic stress disorder mediates the relationship between mild traumatic brain injury and health and psychosocial functioning in veterans of Operations Enduring Freedom and Iraqi Freedom. J Nerv Ment Dis. Oct. 2009;197(10):748-753. [pmid: 19829203].
44 Plassman BL, Havlik RJ, Steffens DC, et al. Documented head injury in early adulthood and risk of Alzheimer's disease and other dementias. Neurology. Oct. 24. 2000;55(8):1158-1166. [pmid: 11071494].
45 Polusny MA, Kehle SM, Nelson NW, Erbes CR, Arbisi PA, Thuras P. Longitudinal effects of mild traumatic brain injury and posttraumatic stress disorder comorbidity on postdeployment outcomes in national guard soldiers deployed to Iraq. Arch Gen Psychiatry. Jan. 2011;68(1):79-89. [pmid: 21199967].
46 Roebuck-Spencer TM, Vincent AS, Twillie DA, et al. Cognitive change associated with self-reported mild traumatic brain injury sustained during the OEF/OIF conflicts. The Clinical Neuropsychologist. Apr. 2012;26(3):473-489. [pmid: 22268558].
47 Romesser J, Shen S, Reblin M, et al. A preliminary study of the effect of a diagnosis of concussion on PTSD symptoms and other psychiatric variables at the time of treatment seeking among veterans. Mil Med. Mar. 2011;176(3):246-252. [pmid: 21456348].
48 Rona RJ, Jones M, Fear NT, et al. Mild traumatic brain injury in UK military personnel returning from Afghanistan and Iraq: cohort and cross-sectional analyses. J Head Trauma Rehabil. Jan-Feb. 2012;27(1):33-44. [pmid: 22241066].
49 Rona RJ, Jones M, Fear NT, Sundin J, Hull L, Wessely S. Frequency of mild traumatic brain injury in Iraq and Afghanistan: are we measuring incidence or prevalence?. J Head Trauma Rehabil. Jan-Feb. 2012;27(1):75-82. [pmid: 22143632].
50 Schneiderman AI, Braver ER, Kang HK. Understanding sequelae of injury mechanisms and mild traumatic brain injury incurred during the conflicts in Iraq and Afghanistan: persistent postconcussive symptoms and posttraumatic stress disorder. Am J Epidemiol. Jun. 15. 2008;167(12):1446-1452. [pmid: 18424429].
51 Skopp NA, Trofimovich L, Grimes J, Oetjen-Gerdes L, Gahm GA. Relations between suicide and traumatic brain injury, psychiatric diagnoses, and relationship problems, active component, U.S. Armed Forces, 2001-2009. Msmr. Feb. 2012;19(2):7-11. [pmid: 22372751].
52 Theeler BJ, Flynn FG, Erickson JC. Headaches after concussion in US soldiers returning from Iraq or Afghanistan. Headache. Sep. 2010;50(8):1262-1272. [pmid: 20553333].
53 Theeler BJ, Flynn FG, Erickson JC. Chronic Daily Headache in U.S. Soldiers After Concussion. Headache. 2012;52(5):732-738. [pmid: 22404747].
54 Vanderploeg RD, Belanger HG, Curtiss G. Mild traumatic brain injury and posttraumatic stress disorder and their associations with health symptoms. Arch Phys Med Rehabil. Jul. 2009;90(7):1084-1093. [pmid: 19577020].
55 Vanderploeg RD, Curtiss G, Belanger HG. Long-term neuropsychological outcomes following mild traumatic brain injury. J Int Neuropsychol Soc. May. 2005;11(3):228-236. [pmid: 15892899].
56 Vanderploeg RD, Curtiss G, Duchnick JJ, Luis CA. Demographic, medical, and psychiatric factors in work and marital status after mild head injury. J Head Trauma Rehabil. Mar-Apr. 2003;18(2):148-163. [pmid: 12802224].
57 Vasterling JJ, Brailey K, Proctor SP, Kane R, Heeren T, Franz M. Neuropsychological outcomes of mild traumatic brain injury, post-traumatic stress disorder and depression in Iraq-deployed US Army soldiers. Br J Psychiatry. Sep. 2012;201:186-192. [pmid: 22743844].
58 Wilk JE, Herrell RK, Wynn GH, Riviere LA, Hoge CW. Mild traumatic brain injury (concussion), posttraumatic stress disorder, and depression in U.S. soldiers involved in combat deployments: association with postdeployment symptoms. Psychosom Med. Apr. 2012;74(3):249-257. [pmid: 22366583].
59 Wilk JE, Thomas JL, McGurk DM, Riviere LA, Castro CA, Hoge CW. Mild traumatic brain injury (concussion) during combat: lack of association of blast mechanism with persistent postconcussive symptoms. J Head Trauma Rehabil. Jan-Feb. 2010;25(1):9-14. [pmid: 20051900].
60 Yurkiewicz IR, Lappan CM, Neely ET, et al. Outcomes from a US military neurology and traumatic brain injury telemedicine program. Neurology. Sep. 18. 2012;79(12):1237-1243. [pmid: 22955133].