# SEARCH STRATEGIES

Database: Ovid MEDLINE(R) and Ovid OLDMEDLINE(R) <1946 to September Week 3 2012>, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations <October 02, 2012>

Search Strategy:

--------------------------------------------------------------------------------

1. exp Brain edema/ (11605)
2. exp cerebrovascular trauma/ (4960)
3. exp craniocerebral trauma/ (113847)
4. exp coma/ (17150)
5. exp glasgow outcome scale/ (1042)
6. exp glasgow coma scale/ (6068)
7. ((brain* or capitis or cerebr* or crani* or hemispher* or inter-crani* or intra-crani* or skull*) adj4 (contusion* or damag* or fractur* or injur* or trauma* or wound*)).ab,ti. (77042)
8. ((brain or crani* or cerebr* or head or inter-cran* or intra-cran*) adj4 (bleed* or haematoma* or haemorrhag* or hematoma* or hemorrhag* or pressure)).ti,ab. (23995)
9. (Glasgow adj (coma or outcome) adj (scale* or score*)).ab,ti. (7439)
10. ‘Rancho Los Amigos Scale’.ti,ab. (31)
11. diffuse axonal injur*.ti,ab. (755)
12. ((brain or cerebral or intracranial) adj3 (edema or oedema or swell*)).ab,ti. (11389)
13. ((coma* or concuss* or unconscious* or ‘persistent vegetative state’) adj2 (damag* or fractur* or injur* or trauma* or wound*)).ti,ab. (1686)
14. (mtbi or “mild trauma* injur*”).tw. or “minor trauma* injur*”.mp. (639)
15. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 (209513)
16. exp cohort studies/ (1212058)
17. exp prognosis/ (967036)
18. exp morbidity/ (328065)
19. exp mortality/ (255922)
20. exp survival analysis/ (158174)
21. exp models, statistical/ (230839)
22. prognos*.tw. (324957)
23. course*.tw. (428896)
24. diagnosed.tw. (303319)
25. cohort*.tw. (221535)
26. death.tw. (417341)
27. predict*.tw. (808663)
28. 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 or 25 or 26 or 27 (3743025)
29. diagnosed.tw. (303319)
30. cohort:.mp. (281196)
31. (predictor: or death).tw. (578864)
32. exp models, statistical/ (230839)
33. prognosis/ (327999)
34. 29 or 30 or 31 or 32 or 33 (1494750)
35. 28 or 34 (3743144)
36. 15 and 35 (67135)
37. exp rehabilitation, vocational/ (8852)
38. exp employment/ (49891)
39. exp work/ (12406)
40. sick leave/ (3365)
41. absenteeism/ (6861)
42. exp occupational health/ (23070)
43. exp occupational medicine/ (21574)
44. exp disabled persons/ (43220)
45. “recovery of function”/ (25824)
46. exp human activities/ (291441)
47. exp self care/ (36358)
48. activities of daily living.tw. (13206)
49. (dressing or feeding or eating or toilet$ or bathing or mobil$ or driving or public transport$).tw. (409253)
50. ((daily or domestic or house or home) adj5 (activit$ or task$ or skill$ or chore$)).tw. (34321)
51. (“work status” or “work capacity”).tw. (4948)
52. (unemployment or re-employment or underemployment or “job retention”).ti,ab. (6217)
53. (return* adj2 school).tw. (428)
54. 37 or 38 or 39 or 40 or 41 or 42 or 43 or 44 or 45 or 46 or 47 or 48 or 49 or 50 or 51 or 52 or 53 (884984)
55. 15 and 54 (12268)
56. exp dementia/ (109281)
57. Delirium/ or exp Delirium, Dementia, Amnestic, Cognitive Disorders/ (165121)
58. dement*.mp. or alzheimer*.tw. (137451)
59. exp Parkinsonian Disorders/ (53442)
60. parkinson*.tw. (67897)
61. 56 or 57 or 58 or 59 or 60 (263117)
62. 15 and 61 (10666)
63. 36 or 55 or 62 (80547)
64. animals/ not (humans/ and animals/) (3693774)
65. 63 not 64 (72473)
66. limit 65 to (danish or english or french or norwegian or spanish or swedish) (62699)
67. limit 66 to yr=“2001 -Current” (36478)
68. exp “Outcome Assessment (Health Care)”/ (605282)
69. (intervention* adj3 stud*).tw. (23915)
70. 68 or 69 (626005)
71. 15 and 70 (12781)
72. 71 not 64 (12055)
73. limit 72 to (yr=“2001 -Current” and (danish or english or french or norwegian or swedish)) (8537)
74. 67 or 73 (36658)
75. randomized controlled trial.pt. (337763)
76. Randomized controlled trial/ (337763)
77. Randomized Controlled Trials as Topic/ (83241)
78. Double-Blind Method/ (117191)
79. clinical trial.pt. (474276)
80. “double blind:”.mp. (143695)
81. placebos/ (31353)
82. placebo:.mp. (158293)
83. random:.mp. (788646)
84. 75 or 76 or 77 or 78 or 79 or 80 or 81 or 82 or 83 (1069355)
85. 15 and 84 (10248)
86. review/ (1739065)
87. (medline or medlars or pubmed or grateful med or CINAHL or scisearch or psychinfo or psycinfo or psychlit or psyclit or handsearch* or hand search* or manual* search* or electronic database* or bibliographic database* or embase or lilacs or scopus or web of science).mp. (74569)
88. 86 and 87 (48085)
89. meta-analysis.mp. (59484)
90. meta-analysis as topic/ (12450)
91. meta-analysis/ (36480)
92. systematic review*.tw. (38103)
93. cochrane database*.jn. (9039)
94. 88 or 89 or 90 or 91 or 92 or 93 (112607)
95. 15 and 94 (1435)
96. exp brain neoplasms/ (111650)
97. (cancer* or neoplasm* or tumor* or malign*).mp. and brain.tw. (75605)
98. exp Glioma/ (55756)
99. 96 or 97 or 98 (164154)
100. 15 and 99 (9656)
101. exp pain/ (283152)
102. exp chronic disease/ (210066)
103. 101 and 102 (20005)
104. (chronic* adj3 pain*).mp. (32890)
105. 103 or 104 (40897)
106. 15 and 105 (366)
107. exp sports/ (100542)
108. exp recreation/ (116143)
109. (return* adj3 play*).tw. (803)
110. 107 or 108 or 109 (116607)
111. 15 and 110 (3782)
112. exp mental disorders/ (880032)
113. 15 and 112 (15929)
114. exp disability evaluation/ (35932)
115. exp “Outcome Assessment (Health Care)”/ (605282)
116. disab:.tw. (119042)
117. 114 or 115 or 116 (728782)
118. 15 and 117 (17459)
119. 74 or 85 or 95 or 100 or 106 or 111 or 113 or 118 (68980)
120. limit 119 to (english language and yr=“2001 -Current” and (danish or english or french or norwegian or swedish)) (43016)
121. animals/ not (humans/ and animals/) (3693774)
122. 120 not 121 (39793)
123. exp “United States Department of Veterans Affairs”/ or exp Veterans Health/ or exp Hospitals, Veterans/ or exp Veterans Disability Claims/ or exp Veterans/ (15311)
124. veteran.mp. (2331)
125. veterans.mp. (23349)
126. VA.mp. (16805)
127. VA.in. (58986)
128. VAMC.mp. (285)
129. VAMC.in. (2086)
130. exp Military Medicine/ or exp “United States Department of Defense”/ or exp Naval Medicine/ (30814)
131. exp Hospitals, Military/ (3861)
132. exp Military Facilities/ (3901)
133. (army or navy or air force or marines or coast guard).mp. [mp=title, abstract, original title, name of substance word, subject heading word, protocol supplementary concept, rare disease supplementary concept, unique identifier] (15842)
134. military.mp. or exp Military Personnel/ (22947)
135. soldier.mp. (1480)
136. soldiers.mp. (5245)
137. 123 or 124 or 125 or 126 or 127 or 128 or 129 or 130 or 131 or 132 or 133 or 134 or 135 or 136 (151164)
138. 122 and 137 (1170)
139. traumatic brain injury.mp. or exp Brain Injuries/ (48119)
140. tbi.mp. (10831)
141. 139 or 140 (51178)
142. 137 and 141 (1468)
143. 138 or 142 (1977)
144. from 143 keep 1-1977 (1977)

***************************

The above search strategy was applied to two additional databases on Oct. 3, 2012, with the following yield:

PsycINFO=961

Cochrane Register of Controlled Trials (OVID)=46