# SUMMARY AND DISCUSSION

## SUMMARY OF EVIDENCE BY KEY QUESTION

A summary of the conclusions and strength of evidence is presented in Table 2.

Table 2 Conclusions and Strength of Evidence by Key Question and Outcome

Conclusion | GRADE Classification
KEY QUESTION #1. What is the association between secure messaging and health outcomes, patient satisfaction, adherence, efficiency or utilization, or automated email?
Health Outcomes
Secure messaging (especially as part of a web-based management system) can improve glucose outcomes in patients with diabetes. | moderate
Adding a web-based pharmacist to secure messaging improves blood pressure outcomes in patients with hypertension. | low
Secure messaging with a web-based management system improves ulcerative colitis symptoms. | low
Patient Satisfaction
Secure messaging increases patient satisfaction. | moderate
Adherence
Secure messaging improves adherence to colorectal cancer screenings or heart failure management. | low
Efficiency/Utilization
Secure messaging influences either positively or negatively efficiency or utilization. | low

Conclusion | GRADE Classification
KEY QUESTION #2. What is the association between patient access to their own medical record and health outcomes, patient satisfaction, adherence, efficiency or utilization, and attitudes about access?
Health Outcomes, Satisfaction, and Adherence
Patients’ access to their own medical record improves health outcomes for chronic diseases such as diabetes, hypertension, or heart failure. | low
Patient access to their own records, combined with the ability to submit an electronic care plan can improve medication decisions at a subsequent visit for patients with diabetes. | low
Efficiency/Utilization
There is insufficient evidence to reach conclusions regarding the potential effect of patients’ access to their own medical record on efficiency | insufficient
Patients’ access to their own medical record influences utilization. | low
Attitudes
There is insufficient evidence to reach conclusions regarding the potential effect on patients’ access to their own medical record on patient attitudes. | insufficient
Patient Characteristics
Use of patient portals is lower among certain racial or ethnic groups, in particular African Americans. | moderate
Use of patient portals is lower in persons with lower literacy or education level. | moderate

## LIMITATIONS

The primary limitation of this systematic review is the quantity and quality of the original studies. Evidence was sparse for all but two of the outcomes assessed (the effect of SM on diabetes outcomes and patient satisfaction), and studies frequently had methodological problems including the use of study designs with greater risk of bias (pre/post studies), poor response rate or poor follow-up rate for surveys and cohort studies, and little explanation of the implementation process for the IT functionality, which has two consequences: it makes it challenging to distinguish between failure of the intervention and failure of the implementation in studies reporting no effect; and for studies that do report beneficial effects it leaves providers and policymakers at other institutions unclear about how to replicate the success. The above limitations are common to almost all systematic reviews of health information technology. An additional limitation of this review is that the functionalities of interest, secure messaging and patient access to their own records, were often part of a bundle of interventions, making attribution of any beneficial effect to any one functionality difficult. In practice, attributing the independent effect of individual functionalities may not be necessary or even meaningful, since many champions consider these two functionalities (plus others) as interdependent. Many champions consider the package of functionalities – secure messaging, patient access to renew medications and appointments, and online disease management tools to be core elements of a tethered personal health record. Additionally, there may be a “ceiling effect” present, meaning that patients practicing greater health engagement with providers and in terms of self-management may be more likely to adopt new technology sooner, making it harder to demonstrate strong improvement. Lastly, much of the evidence comes from non-VA settings – e.g., studies from academic tertiary care medical centers working in a fee-for-service or similar reimbursement environment – although several observational studies from Kaiser and from Group Health Cooperative tend to support the findings from the academic medical centers. The relevance of these settings to VA is a judgment for VA policymakers.

## DISCUSSION

The literature surrounding secure messaging and patient access to their own records is evolving as the systems themselves become more complex. In some respects, evaluating the individual components of patient portals may no longer be relevant since most of the functionalities are not conceptualized as independent features, but rather as part of an overall package that is intended to facilitate information exchange with patients as well as patient communication with providers and healthcare institutions. Our review identifies a few core elements consistently described in most of the published evaluations that comprise the basic patient portal: secure messaging, access to test results, access to progress notes or visit summaries, and educational materials or disease management tools.

The evaluation of the impact of these portals is further complicated when one considers that they are also being designed to align with a larger patient management system that includes case management, remote health care delivery and non-face-to-face care. Attributing outcomes to any one component becomes more and more difficult as these layers are added one to the other; yet it appears that utilizing patient portals as part of a broader effort to improve care, particularly one that involves case management, may in fact yield beneficial results.

These patient portals are also being created as part of a movement to make patients more active participants in their care, as opposed to passive receivers of information. Early consumer health systems provided educational materials to patients. Robust patient portals offer patients the ability to drive and direct their care. Yet our review has identified some potential key barriers to achieving more uniform access to these systems. Successful and widespread implementation will require attention to these disparities in use as well as tailored approaches to engage certain populations that are not readily embracing personal health record systems.

## RECOMMENDATIONS FOR FUTURE RESEARCH

Any research within VA is going to be pragmatic by design, since VA is already implementing secure messaging and patient access to their own record (meaning that any kind of randomized study where this is withheld is not practical). Nevertheless, a time series study of the implementation of secure messaging across institutions would be feasible and could provide reasonable, hypothesis-testing data to assess the effect of increasing SM use on quality (via EPRP), productivity, and patient satisfaction. Such a study would need to use both within-institution and across-institution comparisons to deal with the possibility of secular trends in quality, productivity and satisfaction as well as the “institution effect”.

## CONCLUSIONS

Data are sparse, but support that the use of secure messaging can improve glucose outcomes in patients with diabetes and increase patient satisfaction. Data from other studies suggest that secure messaging as part of a web-based management program is more effective than secure messaging alone. This finding supports the conclusions from other studies of health information technology that HIT is a tool, and if implemented by itself may have modest or even no measurable effect, but HIT can enable the implementation of more comprehensive programs (e.g., the web-based management system, in this case) that have meaningful effects on quality of care.