# REFERENCES

1 Elkjaer M, et al. E-health empowers patients with ulcerative colitis: a randomised controlled trial of the web-guided ‘Constant-care’ approach. Gut. 2010;59(12):1652-61. [pmid: 21071584].
2 Zhou YY, et al. Improved quality at Kaiser Permanente through e-mail between physicians and patients. Health Aff (Millwood). 2010;29(7):1370-5. [pmid: 20606190].
3 Harris LT, et al. Diabetes quality of care and outpatient utilization associated with electronic patient-provider messaging: a cross-sectional analysis. Diabetes Care. 2009;32(7):1182-7. [pmid: 19366959].
4 Tuil WS, et al. Empowering patients undergoing in vitro fertilization by providing Internet access to medical data. Fertil Steril. 2007;88(2):361-8. [pmid: 17416366].
5 McMahon GT, et al. Web-based care management in patients with poorly controlled diabetes. Diabetes Care. 2005;28(7):1624-9. [pmid: 15983311].
6 Ralston JD, et al. Web-based collaborative care for type 2 diabetes: a pilot randomized trial. Diabetes Care. 2009;32(2):234-9. [pmid: 19017773].
7 Green BB, et al. Effectiveness of home blood pressure monitoring, Web communication, and pharmacist care on hypertension control: a randomized controlled trial. JAMA. 2008;299(24):2857-67. [pmid: 18577730].
8 Ross SE, et al. Providing a web-based online medical record with electronic communication capabilities to patients with congestive heart failure: randomized trial. J Med Internet Res. 2004;6(2):e12. [pmid: 15249261].
9 Simon GE, et al. Randomized trial of depression follow-up care by online messaging. J Gen Intern Med. 2011;26(7):698-704. [pmid: 21384219].
10 Lin CT, et al. An Internet-based patient-provider communication system: randomized controlled trial. J Med Internet Res. 2005;7(4):e47. [pmid: 16236699].
11 Leong SL, et al. Enhancing doctor-patient communication using email: a pilot study. J Am Board Fam Pract. 2005;18(3):180-8. [pmid: 15879565].
12 Houston TK, et al. Experiences of patients who were early adopters of electronic communication with their physician: satisfaction, benefits, and concerns. Am J Manag Care. 2004;10(9):601-8. [pmid: 15515992].
13 Liederman EM, Morefield CS. Web messaging: a new tool for patient-physician communication. J Am Med Inform Assoc. 2003;10(3):260-70. [pmid: 12626378].
14 Liederman EM, et al. Patient-physician web messaging. The impact on message volume and satisfaction. J Gen Intern Med. 2005;20(1):52-7. [pmid: 15693928].
15 Muller D, et al. The effectiveness of a secure email reminder system for colorectal cancer screening. AMIA Annu Symp Proc. 2009;2009:457-61. [pmid: 20351899].
16 Weppner WG, et al. Use of a shared medical record with secure messaging by older patients with diabetes. Diabetes Care. 2010;33(11):2314-9. [pmid: 20739686].
17 Santana S, et al. Online communication between doctors and patients in Europe: status and perspectives. J Med Internet Res. 2010;12(2):e20. [pmid: 20551011].
18 Ralston JD, et al. Patient use of secure electronic messaging within a shared medical record: a cross-sectional study. J Gen Intern Med. 2009;24(3):349-55. [pmid: 19137379].
19 Brooks RG, Menachemi N. Physicians’ use of email with patients: factors influencing electronic communication and adherence to best practices. J Med Internet Res. 2006;8(1):e2. [pmid: 16585026].
20 Bergmo TS, et al. Electronic patient-provider communication: will it offset office visits and telephone consultations in primary care?. Int J Med Inform. 2005;74(9):705-10. [pmid: 16095961].
21 Ketteridge G, Delbridge H, Delbridge L. How effective is email communication for patients requiring elective surgery?. ANZ J Surg. 2005;75(8):680-3. [pmid: 16076332].
22 Liederman EM, et al. The impact of patient-physician Web messaging on provider productivity. J Healthc Inf Manag. 2005;19(2):81-6. [pmid: 15869217].
23 Chen C, et al. The Kaiser Permanente Electronic Health Record: transforming and streamlining modalities of care. Health Aff (Millwood). 2009;28(2):323-33. [pmid: 19275987].
24 Zhou YY, et al. Patient access to an electronic health record with secure messaging: impact on primary care utilization. Am J Manag Care. 2007;13(7):418-24. [pmid: 17620037].
25 Tang PC, Black W, Young CY. Proposed criteria for reimbursing eVisits: content analysis of secure patient messages in a personal health record system. AMIA Annu Symp Proc. 2006:764-8. [pmid: 17238444].
26 Katz SJ, Nissan N, Moyer CA. Crossing the digital divide: evaluating online communication between patients and their providers. Am J Manag Care. 2004;10(9):593-8. [pmid: 15515991].
27 Wald JS, et al. Implementing practice-linked pre-visit electronic journals in primary care: patient and physician use and satisfaction. J Am Med Inform Assoc. 2010;17(5):502-6. [pmid: 20819852].
28 McCarrier KP, et al. Web-based collaborative care for type 1 diabetes: a pilot randomized trial. Diabetes Technol Ther. 2009;11(4):211-7. [pmid: 19344195].
29 Grant RW, et al. Practice-linked online personal health records for type 2 diabetes mellitus: a randomized controlled trial. Arch Intern Med. 2008;168(16):1776-82. [pmid: 18779465].
30 Burke RP, et al. Transforming patient and family access to medical information: utilisation patterns of a patient-accessible electronic health record. Cardiol Young. 2010;20(5):477-84. [pmid: 20456816].
31 Earnest MA, et al. Use of a patient-accessible electronic medical record in a practice for congestive heart failure: patient and physician experiences. J Am Med Inform Assoc. 2004;11(5):410-7. [pmid: 15187074].
32 Cho AH, et al. Do diabetic veterans use the Internet? Self-reported usage, skills, and interest in using My HealtheVet Web portal. Telemed J E Health. 2010;16(5):595-602. [pmid: 20575727].
33 Ralston JD, et al. Patient web services integrated with a shared medical record: patient use and satisfaction. J Am Med Inform Assoc. 2007;14(6):798-806. [pmid: 17712090].
34 Hassol A, et al. Patient experiences and attitudes about access to a patient electronic health care record and linked web messaging. J Am Med Inform Assoc. 2004;11(6):505-13. [pmid: 15299001].
35 Volk LA, et al. Patients’ perceptions of a Web portal offering clinic messaging and personal health information. AMIA Annu Symp Proc. 2005:1147. [pmid: 16779433].
36 Eklund B, Joustra-Enquist I. Sustains--direct access for the patient to the medical record over the Internet. Stud Health Technol Inform. 2004;100:182-9. [pmid: 15718578].
37 Dorr DA, et al. Physicians’ attitudes regarding patient access to electronic medical records. AMIA Annu Symp Proc. 2003:832. [pmid: 14728337].
38 Honeyman A, Cox B, Fisher B. Potential impacts of patient access to their electronic care records. Inform Prim Care. 2005;13(1):55-60. [pmid: 15949176].
39 Leonard KJ. The role of patients in designing health information systems: the case of applying simulation techniques to design an electronic patient record (EPR) interface. Health Care Manag Sci. 2004;7(4):275-84. [pmid: 15717812].
40 Pyper C, et al. Patients’ experiences when accessing their on-line electronic patient records in primary care. Br J Gen Pract. 2004;54(498):38-43. [pmid: 14965405].
41 Pai HH, Lau F. Web-based electronic health information systems for prostate cancer patients. Can J Urol. 2005;12(3):2700-9. [pmid: 16011818].
42 Kaelber D, Pan EC. The value of personal health record (PHR) systems. AMIA Annu Symp Proc. 2008:343-7. [pmid: 18999276].
43 Falcao-Reis F, Correia ME. Patient empowerment by the means of citizen-managed Electronic Health Records: web 2.0 health digital identity scenarios. Stud Health Technol Inform. 2010;156:214-28. [pmid: 20543356].
44 Wald JS. Variations in patient portal adoption in four primary care practices. AMIA Annu Symp Proc. 2010:837-41. [pmid: 21347096].
45 Schnipper JL, et al. Design and implementation of a web-based patient portal linked to an electronic health record designed to improve medication safety: the Patient Gateway medications module. Inform Prim Care. 2008;16(2):147-55. [pmid: 18713531].
46 Lyles CR, et al. Patient Race/Ethnicity and Shared Medical Record Use Among Diabetes Patients. Med Care. 2012.
47 Roblin DW, et al. Disparities in use of a personal health record in a managed care organization. J Am Med Inform Assoc. 2009;16(5):683-9. [pmid: 19567790].
48 Sarkar U, et al. The literacy divide: health literacy and the use of an internet-based patient portal in an integrated health system-results from the diabetes study of northern California (DISTANCE). J Health Commun. Suppl 2. 15:183-96. [pmid: 20845203].
49 Yamin CK, et al. The digital divide in adoption and use of a personal health record. Arch Intern Med. 2011;171(6):568-74. [pmid: 21444847].
50 Ralston JD, et al. Patients’ experience with a diabetes support programme based on an interactive electronic medical record: qualitative study. BMJ. 2004;328(7449):1159. [pmid: 15142919].
51 Hess R, et al. Exploring challenges and potentials of personal health records in diabetes self-management: implementation and initial assessment. Telemed J E Health. 2007;13(5):509-17. [pmid: 17999613].
52 Zickmund SL, et al. Interest in the use of computerized patient portals: role of the provider-patient relationship. J Gen Intern Med. Suppl 1. 2008;23:20-6. [pmid: 18095039].
53 Montelius E, et al. Individuals appreciate having their medication record on the web: a survey of attitudes to a national pharmacy register. J Med Internet Res. 2008;10(4):e35. [pmid: 19000978].
54 Urowitz S, et al. Is Canada ready for patient accessible electronic health records? A national scan. BMC Med Inform Decis Mak. 2008;8:33. [pmid: 18652695].
55 Bernheim AM, et al. Early clinical experience with CardioCard - a credit card-sized electronic patient record. Swiss Med Wkly. 2006;136(33–34):539-43. [pmid: 16983596].
56 Kim E, et al. Evaluation of patient-centered electronic health record to overcome digital divide. Conf Proc IEEE Eng Med Biol Soc. 2005;2:1091-4. [pmid: 17282378].
57 Pyper C, et al. Access to electronic health records in primary care-a survey of patients’ views. Med Sci Monit. 2004;10(11):SR17-22. [pmid: 15507869].
58 Balshem H, et al. GRADE guidelines: 3. Rating the quality of evidence. J Clin Epidemiol. 64(4):401-6. [pmid: 21208779].