# EVIDENCE TABLES

Secure Messaging Evidence Table

Patient Access Evidence Tables