# CRITERIA USED IN QUALITY ASSESSMENT

A summary of GRADE’s approach to rating quality of evidence58

Study design | Initial quality of a body of evidence | Lower if | Higher if | Quality of a body of evidence
Randomized trials | High [image] | Risk of Bias −1 Serious | Large Effect +1 Large | High (four plus:⊕⊕⊕⊕)
Observational studies | Low [image] | −2 Very serious | +2 Very large
Observational studies | Low [image] | Inconsistency −1 Serious −2 Very serious | Dose response +1 Evidence of a gradient | Moderate (three plus: ⊕⊕⊕○)
Observational studies | Low [image] | Indirectness −1 Serious −2 Very serious | All plausible residual confounding +1 Would reduce a demonstrated effect | Low (two plus: ⊕⊕○○)
Observational studies | Low [image] | Imprecision −1 Serious −2 Very serious | +1 Would suggest a spurious effect if no effect was observed | Very low (one plus: ⊕○○○)
Observational studies | Low [image] | Publication Bias −1 Likely −2 Very likely