# SEARCH STRATEGY

CONSUMER HEALTH INFORMATION TECHNOLOGY SEARCH METHODOLOGIES

DATABASE SEARCHED & TIME PERIOD COVERED:

PubMed – 1990-12/3/2010

LANGUAGE:

English

SEARCH STRATEGY #1:

“Electronic Health Records”[Mesh] OR “electronic health record” OR “electronic health records” OR “electronic medical record” OR “electronic medical record” OR messaging OR email* OR “computerized alert” OR “computerized alerts” OR “computerized reminder” OR “computerized reminders” OR “computerised reminder” OR “computerised reminders” OR electronics, medical OR informatic*[tiab] OR computerized physician order entry OR computerised physician order entry OR computer provider order entry OR cpoe OR e-prescrib* OR e-prescription* OR electronic prescrib* OR electronic prescription* OR e-health

AND

patient*[ti] OR consumer*[ti] OR patient*[mh] OR consumer*[mh] OR tether* OR secure OR self-report* OR self report*

NOT

case report OR case reports OR case report[pt] OR case reports[pt]

NUMBER OF RESULTS: 2381

SEARCH STRATEGY #2:

“Electronic Health Records”[Mesh] OR “electronic health record” OR “electronic health records” OR “electronic medical record” OR “electronic medical record” OR messaging OR email* OR “computerized alert” OR “computerized alerts” OR “computerized reminder” OR “computerized reminders” OR “computerised reminder” OR “computerised reminders” OR electronics, medical OR informatic*[tiab] OR computerized physician order entry OR computerised physician order entry OR computer provider order entry OR cpoe OR e-prescrib* OR e-prescription* OR electronic prescrib* OR electronic prescription* OR e-health

AND

reminder*

NOT

case report OR case reports OR case report[pt] OR case reports[pt]

NOT

Results of Search Strategy #1

NUMBER OF RESULTS: 353

SEARCH STRATEGY #3:

[“Electronic Health Records”[Mesh] OR “electronic health record” OR “electronic health records” OR “electronic medical record” OR “electronic medical record” OR messaging OR email* OR “computerized alert” OR “computerized alerts” OR “computerized reminder” OR “computerized reminders” OR “computerised reminder” OR “computerised reminders” OR electronics, medical OR informatic*[tiab] OR computerized physician order entry OR computerised physician order entry OR computer provider order entry OR cpoe OR e-prescrib* OR e-prescription* OR electronic prescrib* OR electronic prescription* OR e-health OR “Medical Records Systems, Computerized”[Mesh]

AND

patient*[ti] OR consumer*[ti] OR patient*[mh] OR consumer*[mh] OR tether* OR secure OR self-report* OR self report*

NOT

case report OR case reports OR case report[pt] OR case reports[pt]]

OR

[“Electronic Health Records”[Mesh] OR “electronic health record” OR “electronic health records” OR “electronic medical record” OR “electronic medical record” OR messaging OR email* OR “computerized alert” OR “computerized alerts” OR “computerized reminder” OR “computerized reminders” OR “computerised reminder” OR “computerised reminders” OR electronics, medical OR informatic*[tiab] OR computerized physician order entry OR computerised physician order entry OR computer provider order entry OR cpoe OR e-prescrib* OR e-prescription* OR electronic prescrib* OR electronic prescription* OR e-health OR “Medical Records Systems, Computerized”[Mesh]

AND

reminder*

NOT

case report OR case reports OR case report[pt] OR case reports[pt]]

NOT

Results of Search Strategy #1

NUMBER OF RESULTS: 2804

TOTAL OF ALL SEARCHES AFTER REMOVAL OF DUPLICATES: 4607