# SUMMARY AND DISCUSSION

This systematic review examined outcomes associated with metformin use in T2D populations with traditional contraindications or precautions to receiving metformin. In KQ 1 we assessed the incidence of LA with metformin use among patients with CKD, CHF, CLD, or older age (KQ 1a); we also evaluated the comparative incidence of LA in these populations with use of metformin compared with other antidiabetic agents (KQ 1b). We focused on data published since 2009, when Salpeter et al last updated their Cochrane review of LA with metformin use.^16^ Consistent with prior reviews,^5^ we found that metformin use is associated with an overall low risk of LA among individuals with traditional contraindications or precautions. Identified studies did suggest that patients with CKD may experience a slightly higher rate of LA while using metformin when compared with general diabetes populations; this risk appears highest in individuals with eGFR <30 mL/min/1.73m^2^. We identified no new cases of metformin-associated LA for patients with CHF or CLD and found no data to suggest higher rates of LA with metformin use among older adults. Based on limited available evidence, the comparative risk of LA associated with metformin use among patients with CKD, CHF, or CLD does not appear higher than the risk with use of other hypoglycemic medications. We found no comparative studies examining LA in older adults.

In KQ 2 we examined the incidence of other key outcomes with use of metformin compared with other diabetes medications among patients with T2D and CKD, CHF, CLD, or older age. In patients with T2D and CKD—including some with eGFR down to 30 mL/min—we found that metformin is associated with a lower risk of all-cause mortality compared with non-metformin therapies. In CHF, use of metformin is also associated with a lower risk of all-cause mortality compared with non-metformin therapies. Although data regarding all-cause mortality in CLD and older age were limited, we found no evidence for an association between metformin use and increased all-cause mortality among patients with these precautions. While relatively few studies addressed MACE, metformin appears to be associated with lower rates of CHF readmission among patients with CHF; associations between metformin use and other MACE outcomes are unclear in other populations of interest. Also based on limited evidence, we found no clear association between metformin use and other outcomes of interest (glycemic control, lipid control, weight, hypoglycemia, or vitamin B12 deficiency) in T2D populations with historical contraindications or precautions to receiving metformin.

Overall, data from general diabetes populations has established metformin as effective, unlikely to cause hypoglycemia or weight gain, and possibly associated with reduced cardiovascular events and reduced mortality^1,65,66^; although we found limited data in some areas, there is no evidence to suggest that metformin's positive associations do not hold true in most populations with historical restrictions to metformin use.

## STRENGTH OF EVIDENCE

In Table 9, we summarize the strength of evidence (SOE) for the effects of metformin use on the risk of LA. Using data from 209 RCTs, a prior Cochrane review identified no cases of LA; however, these trials did not recruit individuals with the precautions of interest. We identified 5 observational studies reporting LA in patient using metformin compared to non-metformin users. For cases of CKD, findings were inconsistent, but suggest that rates of LA in patients with CKD may be higher than metformin users overall. For CHF and CLD, there were no cases of LA.

Table 9 Strength of Evidence for Effects of Metformin Use Versus Non-Metformin Use on Risk of LA (KQ 1b)

Study Type | # Studies (Patients) | Findings | SOE Rationale by Domain
LA in patients with CKD, CHF, or CLD
RCTs^a^ | 209 (NR) | No cases, but trials did not recruit patients with contraindications or precautions | Low SOE Moderate ROB, Consistent, Precise, Indirect
Observational | 3 (12,354) | No cases in 2 cohort studies of patients with CHF and 1 study in patients with CLD. | Insufficient SOE Moderate ROB, Consistent, Imprecise, Direct
Observational | 2 (310,214) | Inconsistent findings in 2 studies of patients with CKD | Insufficient SOE Moderate ROB, Inconsistent, Imprecise, Indirect

a Data are from the Cochrane review.^16^

In Table 10, we summarize the SOE for effects of metformin use on mortality and MACE. Because of the observational nature of the vast majority of studies examining this question, no firm conclusions may be drawn. However, in relation to all-cause mortality, in CKD, CHF and older adults, there is uniformly low SOE for fewer deaths among patients taking metformin. Further, in patients with CHF, there is also low SOE that metformin use may lower CHF readmission. There is insufficient evidence to determine whether this benefit may extend to cardiovascular mortality in patients with CHF. Specifically among older adults, there is low SOE that risk of myocardial infarction or stroke may be lower in patients taking metformin.

Table 10 Strength of Evidence for Effects of Metformin Use Versus Non-Metformin Use on Mortality and MACE (KQ 2)

Outcome | # Studies (Patients) | Findings | SOE Rationale by Domain
Patients with CKD
All-cause mortality | 5 observational (33,442) | HR 0.77 (95% CI 0.61, 0.97) 48 fewer deaths/1,000 (81 to 6 fewer) | Low SOE Moderate ROB, Inconsistent, Precise, Direct
Patients with CHF
All-cause mortality | 11 observational (35,410) | HR 0.78 (95% CI 0.71, 0.87) 48 fewer deaths per 1,000 (64 to 29 fewer) | Low SOE Moderate ROB, Consistent, Precise, Direct
Cardiovascular mortality | 3 observational (6,468) | HR 0.77 (0.53, 1.12) 66 fewer deaths/1,000 (136 fewer to 35 more) | Insufficient SOE Moderate ROB, Consistent, Imprecise, Direct
CHF readmission | 4 observational (26510) | HR 0.87 (95% CI 0.78, 0.97) 12 fewer readmissions per 1,000 (20 to 3 fewer) | Low SOE Low ROB, Consistent, Precise, Direct
Older Adults
All-cause mortality | 1 RCT (3,084) 3 observational (184,399) | Risk difference 0.3%, p = 0.88 Lower mortality except in frail older adults | Low SOE Moderate ROB, Inconsistent, Precise, Direct
MACE | 2 observational (345,211) | Lower composite myocardial infarction or stroke, lower MI, lower CHF versus sulfonylurea | Low SOE Low ROB, Consistent, Precise, Direct

## CLINICAL AND POLICY IMPLICATIONS

As the consensus first-line therapy for patients with T2D, metformin is the most widely prescribed diabetes drug in the world.^67^ Beyond its blood sugar–lowering effects, metformin is an appealing diabetes treatment option because it is safe, does not cause weight gain, and may be associated with improved long-term outcomes in general diabetes populations. ^1,65,66^ However, due to concerns about metformin-associated LA,^5^ FDA labeling has traditionally specified renal impairment as a contraindication to metformin use, and acute or unstable CHF, hepatic impairment, and older age as precautions with metformin use. Recently, though, the FDA has relaxed restrictions on metformin prescribing. In April 2016, the FDA issued a statement supporting metformin initiation in patients with an eGFR >45 mL/min/1.73m^2^ and continuation with appropriate monitoring in patients with an eGFR >30-45 mL/min/1.73m^2^.^11^

In the wake of these recent changes in FDA labeling, prescribing of metformin will undoubtedly increase. It has previously been estimated that one million additional patients would become eligible to use metformin in the United States alone if an eGFR cutoff of 30 mL/min/1.73m^2^ were implemented.^68^ It is therefore critically important that clinicians understand the full spectrum of risks and benefits associated with metformin use in populations with historical contraindications and precautions. This systematic review provides a comprehensive, up-to-date evaluation of existing literature regarding multiple key outcomes associated with metformin use in T2D populations with traditional contraindications or precautions. Our findings support FDA's recent actions and will directly inform clinicians' prescribing practices for T2D patients with traditional restrictions to receiving this medication.

This analysis adds to existing knowledge about long-term outcomes of metformin use. Lamanna et al conducted a meta-analysis of randomized trials that suggested an association between metformin monotherapy and improved survival in general diabetes populations.^1^ In contrast, Palmer et al conducted a subsequent network meta-analysis that found no differences in mortality with different antihyperglycemic agents, including metformin.^69^ Our review differs fundamentally from these analyses in that we focused exclusively on diabetes populations with traditional metformin contraindications or precautions. Consequently, we included observational studies with longer follow-up periods, which are better suited to examining associations that require longer exposure to observe (eg, mortality). Our findings regarding CHF are consistent with those of Eurich et al,^18^ who found that metformin is associated with reduced mortality in CHF; our analysis included 3 additional studies (n = 6,514),^27,35,48^ and excluded another that did not employ an active comparator.^70^

In addition to informing clinician practice, this review may help inform the revision of prescribing guidelines within VA and professional societies. The 2016 American Diabetes Association guidelines already note that “accumulating observational data suggest that metformin may be safely continued down to glomerular filtration rate (GFR) of 45 mL/min/1.73m^2^ or even 30 mL/min/1.73 m^2^.”^65^ Our review, together with other reviews and the recent FDA labeling changes, may support strengthening this endorsement.

## STRENGTHS AND LIMITATIONS

This review's strengths include a rigorous methodology, a thorough review of existing literature (which included a search for relevant RCT subgroup analyses), a comprehensive consideration of multiple traditional contraindications and precautions to metformin use, and an evaluation of multiple critical outcomes of interest. However, our approach has some limitations. First, because a Cochrane review described the risk of LA with metformin use based on literature published through 2009, we limited our KQ 1 literature search to articles published after this time. We limited our literature search for KQ 2 to articles published after 1994—the year FDA approved use of metformin in the United States. While it is possible we may not have captured relevant articles published before these dates, we searched the reference lists of prior published reviews and consulted content experts to ensure that no critical data were overlooked.

Second, in order to assure relevance for our VA stakeholders, we limited our search to studies conducted in OECD countries. Although this approach may have excluded some potentially relevant articles from non-OECD countries, we feel that this decision enhances the applicability of our findings to our target population. Third, although we examined numerous relevant outcomes as informed by our VA stakeholders and technical expert panel, we did not examine all outcomes of potential interest. Because our primary interest was providing data to inform the safe prescribing of metformin in populations with traditional contraindications and precautions, we focused on outcomes we feel would be the most clinically relevant for prescribers.

Beyond these limitations, the existing evidence base calls for additional caution in interpreting our findings. The studies we identified were primarily observational and, as such, come with potential limitations. First, although most included studies attempted to account for baseline differences between metformin and non-metformin populations through statistical adjustment (and in some cases, propensity score matching), confounding by indication remained a potential source for measured and unmeasured population differences. For example, most studies did not closely examine precaution severity; multiple studies included all patients whose eGFR fell below a certain cutoff or all patients with CHF diagnosis codes without accounting for ejection fraction. Unaccounted-for between-group differences in precaution severity could therefore have influenced our findings. Second, while some studies analyzed outcomes based on specific time intervals during which patients were or were not exposed to metformin, most studies defined metformin use at baseline only. As a result, some patients categorized as metformin-exposed could have discontinued metformin, and some unexposed patients could potentially have initiated treatment after baseline. Third, it is likely that different comparator therapies were utilized in different study populations. Most studies (including nearly all meta-analyzed studies) sought to compare T2D patients whose treatment regimens included metformin to those whose did not. As such, intervention and comparator patients alike may have used sulfonylureas, insulin, and other common diabetes medications, preventing assessment of outcomes with metformin versus specific comparators. We found few explicit comparisons to newer anti-diabetic agents like DPP-4 inhibitors, GLP-1 receptor agonists, or SGLT-2 inhibitors. Fourth, studies used different strategies for assessing outcomes of interest; this issue was particularly relevant for LA, where varying outcome assessment definitions contributed to markedly different incidence estimates. Fifth, the timing of outcome assessment varied between studies, and little information was typically provided on attrition in study populations. All of these factors may have contributed to the heterogeneity on our qualitative and quantitative syntheses. However, because most meta-analyzed studies showed metformin use to be associated with improved outcomes of interest, the heterogeneity identified in our analyses appears related to variance in the precise magnitude of an overall consistent effect favoring metformin.

Of note, because our syntheses relied on observational data, we were limited in our ability to assess publication bias as part of our review. Existing study registries (eg, ClinicalTtrials.gov) do not apply to observational studies, which precluded a statistical analysis of publication bias.

## FUTURE RESEARCH

To date, many diabetes pharmacotherapy RCTs have excluded patients with CKD, advanced CHF, and other historical contraindications or precautions to metformin use. As such, the primary gap in the current evidence regarding metformin use in populations with traditional contraindications and precautions is the lack of randomized trials in this domain. Currently, various factors reduce the feasibility of conducting RCTs addressing the use of metformin in populations with traditional contraindications and precautions, including the fact that metformin is a generic medication widely considered to be the consensus first-line treatment for T2D. The length of time required for appropriate assessment of relevant outcomes may also be prohibitive. A large pragmatic trial akin to the Diuretic Comparison Project, an ongoing VA Cooperative Study comparing hydrochlorothiazide and chlorthalidone for cardiovascular risk reduction in hypertension,^71^ may be a feasible strategy for assessing the comparative effectiveness of metformin and other agents among patients with historical contraindications and precautions. Even without RCTs, new observational studies will remain important to ensure that rates of metformin-associated LA do not rise as metformin prescribing increases among populations with traditional contraindications (especially CKD). As the use of newer diabetes classes becomes more prevalent within VA, observational studies will remain a viable approach for comparing metformin with newer agents in these populations.

The impact of contraindication or precaution severity on the apparently beneficial effects of metformin remains unclear based on available data. For example, while our primary CKD meta-analysis did include patients with eGFR down to 30 mL/min/1.73m^2^, additional studies focusing specifically on cohorts with eGFR 30-45 mL/min/1.73m^2^ or even <30mL/min/1.73m^2^ would further inform prescribing of metformin in these groups, and refinement of clinical guidelines. Data regarding the impact of precaution severity in CHF, CLD, and older age are sparse, and further observational research could address these gaps.

Building on the issue of severity, the possibility of tailoring prescribing recommendations based on the severity of historical contraindications or precautions would benefit from further research. For example, metformin dose reduction based on eGFR has long been recommended in Canadian prescribing guidelines,^72^ and US thought leaders have recently suggested a maximum metformin dose of 2550 mg for patients with eGFR >60, 2000 mg daily for eGFR 45-<60 mL/min/1.73m^2^ and 1000 mg/day for eGFR 30-<45 mL/min/1.73m^2^.^5^ Given that the kidneys excrete metformin unchanged in the urine,^73^ the idea of such dose adjustment has a clear rationale, but at this time there are no experimental data and limited observational data to support such an approach.

Finally, data were particularly limited for certain conditions (eg, CLD) and outcomes of interest beyond mortality (eg, MACE, hypoglycemia); future observational research is warranted to explore these areas in greater detail. It will also be crucial to evaluate whether the mortality benefit associated with metformin use persists as prescribing in populations with historical contraindications and precautions expands.

## CONCLUSIONS

Based on limited evidence, the rate of LA associated with metformin use among patients with historical contraindications or precautions does not appear higher than that of other diabetes medications. Metformin appears to be associated with reduced all-cause mortality in patients with CKD and patients with CHF, and appears to be associated with reduced CHF readmission in patients with CHF. Though data are otherwise limited, other risks of metformin use do not appear higher than those associated with other diabetes medications among patients with historical contraindications or precautions. Despite this review's limitations, our findings support recent FDA labeling changes, may help inform clinical practice and revision of clinical guidelines, and point toward important areas for future research.