# RESULTS

## LITERATURE FLOW

Figure 1 shows the flow of articles through the literature search and screening process. The literature search identified 4,841 unique citations from a combined search of MEDLINE^®^ (via PubMed^®)^, the Cochrane Registry of Controlled Trials, Embase^®^, and International Pharmaceutical Abstracts. An additional 8 articles were identified from manual searches of bibliographies and current literature published after the search date for a total of 4,849 unique citations. After applying inclusion and exclusion criteria at the title-and-abstract screening level, 523 full texts were retrieved for further review. Of these, 37 were retained for data abstraction. We attempted to contact 13 authors for additional study information; however, 7 could not be reached, and the remaining 6 all replied that the data were not available.

Figure 1 Literature Flow Chart

* Search results are from Embase (2512), PubMed (2312), Cochrane (17).

** The report's reference list includes all the studies (CHF/cardiovascular studies, n = 18; the remaining studies are elderly). One of the included studies is a companion paper.

Among the 37 included studies, 29 were observational studies and 8 were randomized controlled trials (RCTs), of which one was a companion paper. Some studies reported results applicable to more than one key question (KQ) or one precaution or contraindication. By KQ, 9 studies addressed KQ 1 and 32 studies addressed KQ 2. By precaution, studies reported data relevant to older adults (n = 16), patients with CHF (n = 11), patients with CKD (n = 9), and patients with CLD (n = 3). Most studies were conducted in samples from Europe and used a retrospective cohort design; 4 studies were conducted in Veteran samples. Of note, we identified no ongoing studies meeting our inclusion criteria in Clinical Trials.gov.

## KEY QUESTION 1 For patients with type 2 diabetes and an apparent contraindication/precaution to metformin use (eg, renal insufficiency, congestive heart failure, chronic liver disease, or older age)

a. What is the rate of lactic acidosis in patients taking metformin?
b. How does the rate of lactic acidosis in patients taking metformin compare with the rate in patients taking other hypoglycemics?

### Key Findings

- There are limited new data examining the rate of lactic acidosis (LA) with metformin use since the 2010 Cochrane review; however, a small number of contemporary studies have reported on this outcome in individuals with an identified precaution or contraindication to metformin use.
- KQ 1a: Limited data suggest that the incidence of LA in metformin users who have chronic kidney disease (CKD) is slightly higher than the upper bounds (4.3/100,000) reported in the Cochrane review. The limited data on incidence rates of LA among older adults are inconclusive. No studies reported incidence rates for individuals with CHF or chronic liver disease (CLD).
- KQ 1b: The data comparing rates of LA with metformin use versus non-metformin diabetes treatment do not suggest a higher rate of LA with metformin use among individuals with CKD, CHF, or CLD. No study reported this outcome for older adults without one of these comorbid conditions.

Recommendations regarding the use of metformin in the treatment of type 2 diabetes (T2D) are limited by concerns of the development of fatal or nonfatal LA among individuals with a contraindication to metformin therapy. In 2010, Salpeter et al published a scientifically rigorous Cochrane review of studies through 2009 describing the rate of fatal and nonfatal LA with metformin use in patients with T2D.^16^ The authors found no cases of LA in 70,490 patient-years of metformin use using pooled data from 347 comparative trials and cohort studies. Using Poisson statistics, the upper 95% confidence interval (CI) for the rate of LA was estimated at 4.3 per 100,000 person-years in metformin users and 5.4 per 100,000 person-years in nonusers. However, there was insufficient information to estimate the number of participants studied with renal insufficiency, cardiovascular diseases, or liver disease. As an update to those findings, our review describes results in patients with a precaution/contraindication to metformin from publications in years 2009 through 2015.

Since 2009, 9 observational studies have evaluated the rate of LA in individuals with T2D taking metformin and a contraindication/precaution to its use.^25,33-40^ We did not identify any RCTs enrolling patients with a precaution/contraindication or reporting relevant subgroup analyses for this outcome. Seven of the 9 studies were conducted in Europe,^25,33-35,37,39,40^ one in North America,^38^ and one in Japan.^36^ All 9 studies evaluated the rate of LA in individuals taking metformin; 5 studies compared the rate of LA in metformin users with the rate in individuals taking other hypoglycemics.^25,34,35,38,40^ Due to significant heterogeneity across studies and metformin precautions, a meta-analysis was not performed and studies were synthesized qualitatively.

For KQ 1, we present the detailed results by condition, starting with incidence (KQ 1a) and then comparison (KQ 1b). Details on study characteristics are in Appendix F.

### Rate of Lactic Acidosis with Metformin Use

Four studies examined the rate of LA among individuals taking metformin alone or in combination with another diabetic medication.^33,36,37,39^ There were no studies evaluating the individual effect of metformin on the occurrence of LA among individuals with CHF or CLD.

#### Chronic Kidney Disease

Two studies focused on the rate of LA in individuals with CKD.^33,39^ Of these, one prospective study with high risk of bias (ROB) included 588 French patients older than age 65 and evaluated the appropriateness of metformin dosing based on baseline estimated glomerular filtration rate (eGFR), which was derived using Cockcroft-Gault corrected for body surface area, or CKD-EPI estimating equations.^39^ Over an average follow-up of 3 years, there were no reported deaths due to LA irrespective of the appropriateness of metformin dosing. The study does not comment on the occurrence of nonfatal LA and does not present a time-adjusted analysis.

The other study used records from a large UK database to examine the rate of LA in individuals on metformin with normal, mildly impaired, moderately impaired, or severely impaired renal function.^33^ CKD categories were based on diagnosis code of CKD stage or eGFR. This retrospective, high ROB study included 77,601 patients and 337,590 patient-years, during which there were 35 LA events (captured by ICD-9 code) over an average follow-up of 4.35 years. The overall rate of LA in individuals receiving metformin was 10.37 per 100,000 patient years (95% CI 7.22 to 14.42), higher than the estimate reported in the Cochrane review. The rate of LA by eGFR category was 7.61, 4.64, 17.18, and 39.0 per 100,000 patient-years among eGFR >90 (normal), >60 to ≤90 (mildly impaired), >30 to ≤60 (moderately impaired), and ≤30 ml/min/1.73m^2^ (severely impaired), respectively. There were no statistically significant differences in the incidence rate ratio (IRR) of LA across mildly, moderately, and severely impaired renal function compared with normal renal function (IRR 0.61 [95% CI 0.12 to 5.26], 2.27 [0.56 to 20.0], 5.26 [0.37 to 71.43], respectively), but confidence intervals were wide and did not exclude a clinically significant difference.

#### Older Adults

Two studies examined the rate of LA among older metformin users. One small pharmacovigilance study with high ROB evaluated the rates of elevated lactate or LA among 180 Japanese adults ≥65 years of age retrospectively studied for one year.^36^ The most commonly used metformin dose was 750mg per day. There was no significant difference in elevated lactate level between elderly and nonelderly individuals, and no cases of LA were identified. A second study used a central Swedish registry to retrospectively identify the occurrence of LA (lactate levels >5mmol/L and serum pH <7.35).^37^ Median age was 67 (Table 3). Over 2 years, there were 3 cases of LA (ages 65, 73, 75), among 5,408 individuals (equivalent to 27.7 per 100,000 person years), one of which was found to have metastatic pancreatic cancer and died the subsequent day. This is substantially higher than the rate of LA reported in the Cochrane review.

Table 3 Rate of LA with Metformin Use

Study Country | Precaution Analysis Sample | Outcome
Becquemont, 2015^39^ France | CKD: eGFR category based on metformin adaptation n = 588 | Fatal LA: none over a mean follow-up of 3 years
Richy, 2014^33^ UK | CKD: eGFR >90, >60-90, >30-60, <30 n = 77,601 | LA based on ICD-9: 10.3 per 100,000 patient years over a mean follow-up of 4.35 years. Rates did not differ by category of renal impairment
Ito, 2014^36^ Japan | Older adults ≥65 n = 180 | LA based on laboratory data: none over 1 year follow-up No difference in lactate levels
Sterner, 2012^37^ Sweden | Older adults n = 5,408 | LA based on lactate >5mmol/L and pH <7.35: 3 cases over 2 year follow-up

Abbreviations: CHF = congestive heart failure; CKD = chronic kidney disease; eGFR = estimated glomerular filtration rate; ICD = International Classification of Diseases; LA = lactic acidosis; ROB = risk of bias

### Lactic Acidosis with Metformin Use Compared with Other Hypoglycemic Medications

Five studies evaluated the rate of LA with metformin use compared with other hypoglycemic medications.^25,34,35,38,40^ There were no studies comparing the rate of LA with metformin use versus other hypoglycemic medications in older adults.

#### Chronic Kidney Disease

Two studies with moderate ROB compared the rate of LA with metformin use versus other hypoglycemic medications among individuals with CKD.^34,40^ The first study, performed in a Swedish pharmaceutical database, was a retrospective cohort study using a composite definition of acidosis/serious infection, categorized as fatal or any.^40^ Compared with metformin monotherapy, the risk of the any acidosis/serious infection was increased with insulin monotherapy (HR 1.37, 95% CI 1.26 to 1.50) or other oral hypoglycemic agent (OHA) monotherapy (HR 1.16, 95% CI 1.04 to 1.28). The relative rates of LA or serious infection were also reported by renal function, using other OHAs as the referent. Metformin compared with other OHAs showed lower rates of LA or serious infection in patients with eGFR ≥60ml/min/1.73m^2^ (HR 0.91, 95% CI 0.84 to 0.98) and eGFR 45 to <60 (HR 0.85, 95% CI 0.74 to 0.97) and no increased risk in patients with eGFR 30 to 45 (HR 0.98, 95% CI 0.79 to 1.21).

The second study, also with moderate ROB, compared risk of LA among metformin users with never users of a noninsulin antidiabetic drug (NIAD).^34^ Over a mean follow-up of 4.3 years, the overall incidence rate of LA or elevated lactate concentrations (>5mmol/L) was 7.4 events per 100,000 person-years among metformin users compared with 2.2 events per 100,000 person-years among NIAD users. Current metformin users had an increased, albeit not statistically significant, risk of LA or elevated lactate compared with NIAD users who had never used metformin, HR 4.03 (0.97 to 16.8). Subgroup analysis by renal function category (eGFR ≥ 60, 45 to 59, 30 to 44, <30ml/min/1.73m^2^) revealed an adjusted HR of composite LA outcome in metformin users compared with never users of 2.87 (95% CI 0.67 to 12.3), 6.06 (1.37 to 27.1), 5.47 (1.05 to 28.5), 25.7 (3.57 to 185), respectively. The different comparative rates of LA reported in these 2 studies may be related to outcome assessment, with the former study using diagnosis codes for acidosis, serious infection, shock or acute renal failure as proxies for LA, while the latter study used both diagnosis codes for LA and serum lactate levels to define the outcome of interest.

#### Congestive Heart Failure

A study with moderate ROB evaluated the safety of metformin use among 10,920 heart failure patients (diagnosed by ICD 9 code) with T2D.^25^ Danish individuals taking various permutations of metformin, sulfonylurea, and or insulin therapy were followed for a median of 844 days, during which there were no documented reports of LA across all therapies. A prospective study with low ROB from Spain evaluated the effect of newly initiated metformin therapy in individuals with new-onset heart failure (based on Framingham criteria) and previously unknown T2D.^35^ The authors matched 592 heart failure patients with T2D not treated with metformin to 592 patients who began metformin therapy. Over a median follow-up of 56.7 months, there were no cases of LA in either group.

#### Chronic Liver Disease

A single study with low ROB from the United States evaluated the risk of metformin use in individuals with cirrhosis and T2D.^38^ Individuals on metformin at the time of cirrhosis diagnosis were categorized into those who continued on metformin therapy and those who discontinued metformin use. The majority (172, 68.8%) of individuals continued metformin therapy whereas 78 (31.2%) discontinued use following a cirrhosis diagnosis. The median duration of metformin use in those who continued therapy was 26.8 months. Over a median survival of 11.8 years in those who continued metformin and 5.6 years in those who discontinued metformin, there were no reported cases of LA in either group (Table 4). Characteristics of studies evaluating the rate of LA with metformin use compared with other hypoglycemic medications.

Table 4 Rate of LA with Metformin Use Compared with Other Hypoglycemic Medications

Study Country | Precaution Analysis Sample | Comparison | Outcome
Ekstrom, 2012^40^ Sweden | CKD: eGFR category (30 to <45, 45 to <60, ≥60ml/min/1.73m^2^) n = 51,675 | Metformin versus use of other oral antidiabetic agent (dose NR) | LA or serious infection: lower in eGFR ≥60ml/min and 45 to <60; no increase in eGFR 30 to 45 over a mean follow-up of 3.9 years.
Eppenga, 2014^34^ Great Britain | CKD: eGFR category >60, 45-59, 30-44, <30 n = 258,539 | Metformin versus never use of metformin but current use of other NIAD | LA: 7.4/100,000 vs 2.2/100,00 persons-years, p = NS, over mean follow-up of 4.3 years
Andersson, 2010^25^ Denmark | CHF: First CHF hospitalization based on diagnostic codes n = 10,920 | Multiple comparator arms | LA : none in any group over a median follow-up of 844 days
Romero, 2013^35^ Spain | CHF: Framingham criteria n = 1,184 | Metformin versus no metformin use | LA: none reported over a median 56.9 months follow-up
Zhang, 2014^38^ US | CLD: Biopsy-proven cirrhosis with additional clinical evaluation N = 250 | Continued metformin versus discontinued metformin use | LA: none in either group over 5-10 years follow-up

Abbreviations: CHF = congestive heart failure; CKD = chronic kidney disease; eGFR = estimated glomerular filtration rate; ICD = International Classification of Diseases; LA = lactic acidosis; ROB = risk of bias

### Quality of Evidence for Key Question 1

Studies examining the rate of LA among metformin users with a precaution used observational designs and were judged high ROB. Frequent quality issues were incomplete adjustment for difference in baseline characteristics, unequal follow-up, and outcomes assessed with knowledge of the intervention or with measures that included events other than LA. With the exception of unequal baseline characteristics, similar issues were observed for studies comparing rates of LA in metformin users versus nonusers. Due to significant heterogeneity across studies and contraindications, meta-analysis was not performed.

### Summary of Findings

Based on our qualitative synthesis of observational evidence, the risk of LA with metformin use among individuals with a precaution appears to be low. Risk of LA with metformin use does not appear to be higher than the risk of LA with other hypoglycemic medications. In patients with CKD, the risk of LA with metformin use appears to be highest in individuals with eGFR <30ml/min/1.73m^2^. In limited studies of patients with CHF, there were no cases of LA with metformin use. A single study evaluating the rate of LA with metformin use in cirrhosis reported no cases of LA. Reports on the risk of LA among older adults are conflicting.

## KEY QUESTION 2 For patients with type 2 diabetes and an apparent contraindication/precaution to metformin use, what are the potential benefits and harms (other than lactic acidosis) of continued treatment with metformin?

### Key Findings

- Among patients with medically treated T2D and CKD, metformin use is associated with a significantly lower risk of all-cause mortality when compared with non-metformin treatment (high heterogeneity present on meta-analysis); limited evidence was identified for major adverse cardiovascular events (MACE).
- Among patients with medically treated T2D and CHF, metformin use is associated with a significantly lower risk of all-cause mortality and heart failure readmission when compared with non-metformin treatment, but risk of cardiovascular mortality did not differ (moderate-to-high heterogeneity present on meta-analyses).
- Among patients with medically treated T2D and CLD with cirrhosis, limited evidence suggests that a lower risk of all-cause mortality may be associated with metformin use when compared with non-metformin treatment.
- Among patients with medically treated T2D and older age (generally age ≥ 65 years), limited evidence suggests that, compared with non-metformin treatment, metformin may be associated with a lower risk of all-cause mortality and some MACE outcomes.
- No evidence was identified regarding the effects of metformin on glycemic control, lipid control, weight, hypoglycemia, or vitamin B12 deficiency among patients with medically treated T2D and CKD, CHF, or CLD; additionally, no evidence was identified for MACE in CLD.
- While limited evidence suggests that progressively lower estimated glomerular filtration rate (eGFR) may diminish the mortality benefit associated with metformin use, the impact of CHF severity, CLD severity, and increasing older age on the effects of metformin is unclear.

For KQ 2, we present the detailed results ordered by precaution (CKD, CHF, CLD, and older age) and, within precaution, by major outcomes. Details on study characteristics are in Appendix F. Further details on results for older adults by study design are in Appendix G.

### Chronic Kidney Disease

Five studies – all of which used observational cohort designs (4 retrospective,^40-43^ one prospective^44^) – evaluated the effect of metformin on KQ2 outcomes in patients with T2D and CKD. Two studies were conducted in the United States,^41,42^ 2 in Europe (Sweden and UK),^40,43^ and one across multiple continents.^44^ One study was conducted specifically among Veterans using VA data.^41^ Three studies reported government funding only,^40-42^ one reported industry funding only,^43^ and one reported both industry and foundation funding.^44^

#### All-cause Mortality

All 5 studies evaluated the effect of metformin on all-cause mortality compared with non-metformin treatments in adults with T2D and CKD. Two studies had low risk of bias (ROB)^41,43^ and 3 had moderate ROB.^40,42,44^ In all, these studies involved 33,442 patients with CKD; while the entire population had CKD in 3 studies,^40-42^ we examined a CKD subgroup in the remaining 2.^43,44^ Individual study sample sizes ranged from 1,246 to 11,481 patients with CKD. Mean follow-up periods ranged from one to 3.9 years.

The mean/median age of study participants ranged from approximately 65 to 76 years. CKD definitions varied between studies, with 3 reporting eGFR-based definitions^40,41,44^ and 2 using serum creatinine-based definitions.^42,43^ Two studies provided outcomes by CKD severity subcategory,^40,44^ while the other studies did not provide data on CKD severity. Only one study reported the population's median metformin dose (1100mg to 1900mg daily in different subgroups).^40^ Mortality was defined using medical record or administrative data for the 4 retrospective studies, while the single prospective study determined mortality on 2-year follow-up assessment.^44^ All studies performed statistical adjustment based on multiple baseline population differences between metformin users and nonusers; 2 studies utilized propensity score matching.^41,44^

Individually, most studies indicated that metformin use was associated with lower mortality when compared with non-metformin treatment. These studies were deemed to have sufficient conceptual homogeneity to perform quantitative synthesis. Based on meta-analysis of all patients (Figure 2), there was a statistically significant summary hazard ratio (HR) for mortality favoring metformin (HR 0.78, 95% CI 0.63 to 0.96). Significant statistical heterogeneity was present. Two studies reported mortality by CKD severity subcategory and suggested that patients with eGFR <45 mL/min/1.73m^2^ experienced less benefit with metformin (Figure 2).^40^ A sensitivity analysis that excluded a subgroup of 573 patients specifically identified by one study as having eGFR <30 mL/min/1.73m^2^ produced similar findings to the overall meta-analysis.^44^

Figure 2 Meta-analysis of All-cause Mortality with Use of Metformin Versus Non-metformin Treatment Among Patients with CKD^a^,^b^

^a^ Studies on the forest plot are ordered by increasing CKD severity.

^b^ Eckstrom, 2012, and Roussel, 2010, stratified their respective populations by eGFR; these eGFR categories are presented separately for these studies.

#### Major Adverse Cardiovascular Events

Two studies evaluated the effect of metformin on MACE versus non-metformin treatments in adults with T2D and CKD, both of which had moderate ROB.^40,42^ In all, these studies reported MACE outcomes in 14,408 patients with CKD. One study included a subgroup of 8,549 patients with CKD (mean age approximately 65 years) followed for a mean of 3.9 years,^40^ while the other included a subgroup of 5,859 patients with CKD (mean age approximately 76 years) followed for a mean of one year.^42^

One study used an eGFR-based definition of CKD (with reporting of CKD subcategories),^40^ while the other used a serum creatinine-based definition.^42^ Only one study reported the population's median metformin dose (1100mg to 1900mg daily in different subgroups).^40^ Both studies utilized different MACE outcomes; one used administrative data to identify MACE-associated diagnosis codes,^40^ and the other used administrative data to identify readmission for heart failure.^42^ Both studies performed statistical adjustment based on multiple baseline population differences between metformin users and nonusers.

Given the low number of studies and differences in MACE outcomes presented, quantitative synthesis was not attempted. One study found no statistically significant difference in MACE-associated diagnoses between metformin users and nonusers with eGFR 45 to <60 (n = 6655, HR 0.94, 95% CI 0.84 to 1.05) or 30 to <45 (n = 1894, HR 1.00, 95% CI 0.83 to 1.19).^40^ The other study found that metformin use was significantly associated with slightly lower CHF readmission (n = 5859, HR 0.91, 95% CI 0.84-0.99).

#### Other Outcomes

No studies were identified that evaluated the effect of metformin on other outcomes of interest (glycemic control, lipid control, hypoglycemia, weight gain, B12 deficiency) in adults with T2D and CKD.

### Congestive Heart Failure

Eleven studies—all of which used observational designs (8 retrospective cohort,^25,26,41,42,45-48^ 2 prospective cohort,^35,44^ and one nested case-control^27^)—evaluated the effect of metformin on KQ 2 outcomes in patients with T2D and CHF. Six studies were conducted in the United States,^27,41,42,46-48^ 3 in Europe,^25,35,45^ one in Canada,^26^ and one across multiple continents.^44^ One study was conducted specifically among Veterans using VHA data.^41^ Six studies reported government funding only,^25,35,41,42,46,48^ one reported foundation funding only,^45^ 2 reported both government and foundation funding,^26,47^ one reported both industry and foundation funding,^44^ and one did not report funding.^27^

#### All-cause Mortality

All 11 studies evaluated the effect of metformin on all-cause mortality versus non-metformin treatment in adults with T2D and CHF. Two studies had low ROB^35,41^ and the others had moderate ROB. In all, these studies involved 35,410 patients with CHF; while the entire population had CHF in 9 studies,^25-27,35,41,42,45-47^ we examined a CHF subgroup in the remaining 2.^44,48^ Individual study sample sizes ranged from 346 to 13,930 patients with CHF. Mean follow-up periods ranged from one to 4.7 years.

The mean/median age of study participants ranged from approximately 55 to 77 years. CHF definitions varied widely between studies, with most using diagnosis codes. CHF severity was likewise reported variably, with 4 studies reporting left ventricular ejection fraction-based definitions,^35,41,42,47^ 2 reporting New York Heart Association-based definitions (both of which also reported left ventricular ejection fraction data),^35,47^ and 2 reporting other clinical definitions (eg, “decompensated heart failure” or “moderate-to-severe heart failure”).^25,46^ The remaining 5 studies did not report CHF severity.^26,27,44,45,48^ No studies reported mortality for specific CHF severity subgroups. No studies reported their population's median metformin dose. Mortality was defined using medical record or administrative data for 9 studies.^25,27,35,41,42,45-48^ One prospective study determined mortality on 2-year follow-up assessment^44^ and one study did not report how mortality was defined.^26^ All studies performed statistical adjustment based on multiple baseline population differences between metformin users and nonusers; 4 studies utilized propensity score matching.^26,27,41,44^

These studies were deemed to have sufficient conceptual homogeneity to perform quantitative synthesis. Based on meta-analysis of all patients, there was a statistically significant summary HR for mortality favoring metformin (Figure 3). Moderate heterogeneity was present. Two studies reported mortality by CHF subcategory. One reported mortality by LVEF category and found no difference with metformin use in subgroups with moderate CHF (LVEF 30% to 39%; HR 0.87; 95% CI 0.67 to 1.13) or severe CHF (LVEF <30%; HR 0.87; 95% CI 0.69 to 1.08).^42^ The other included only patients with LVEF <40% and found no mortality difference with metformin use (HR 0.79; 95% CI 0.36 to 1.71).^47^

Figure 3 Meta-analysis of All-cause Mortality with Use of Metformin Versus Non-metformin Treatment Among Patients with CHF^a^

^a^ Studies on the forest plot are ordered chronologically.

#### Major Adverse Cardiovascular Events

Six studies evaluated the effect of metformin on MACE outcomes versus non-metformin treatments in adults with T2D and CHF.^25-27,35,41,42^ Two studies had low ROB^35,41^ and the others had moderate ROB. In all, these studies involved 26,510 CHF patients with CHF readmission as an outcome and 6,468 with cardiovascular mortality as an outcome; also, in all 6 studies, the entire population had CHF. Individual study sample sizes ranged from 981 to 13,390 patients with CHF. Mean follow-up periods ranged from one to 4.7 years.

The mean/median age of study participants ranged from approximately 55 to 77 years. Most studies used diagnosis codes to define CHF. CHF severity was reported variably, with 3 studies reporting left ventricular ejection fraction-based definitions,^35,41,42^ one reporting a New York Heart Association-based definition (also reported left ventricular ejection fraction data),^35^ and one reporting a clinical definitions ( “decompensated heart failure”).^25^ The remaining 2 studies did not report CHF severity.^26,27^ No studies reported MACE outcomes for specific CHF severity subgroups. No studies reported their population's median metformin dose. Two MACE outcomes were reported by these studies: CHF readmission and cardiovascular mortality. CHF readmission was reported by 4 studies,^27,35,41,42^ all of which defined this outcome using medical record or administrative data. Cardiovascular mortality was reported by 3 studies, 2 of which defined this outcome using medical record or administrative data,^25,35^ and one of which did not report how the outcome was defined.^26^ All studies performed statistical adjustment based on multiple baseline population differences between metformin users and nonusers; 3 studies utilized propensity score matching.^26,27,41^

These studies were deemed to have sufficient conceptual homogeneity to perform quantitative synthesis; we performed separate meta-analyses for each MACE outcome. Based on meta-analysis of available patients, there was a small but statistically significant summary HR for CHF readmission favoring metformin (Figure 4) though high heterogeneity was present. The summary HR for cardiovascular mortality also favored metformin (Figure 5) but was not statistically significant; high heterogeneity was present.

Figure 4 Meta-analysis of CHF Readmission with Use of Metformin Versus Non-metformin Treatment Among Patients with CHF^a^

^a^ Studies on the forest plot are ordered chronologically.

Figure 5 Meta-analysis of Cardiovascular Mortality with Use of Metformin Versus Non-metformin Treatment Among Patients with CHF^a^

^a^ Studies on the forest plot are ordered chronologically.

#### Other Outcomes

No studies were identified that evaluated the effect of metformin on other outcomes of interest (glycemic control, lipid control, hypoglycemia, weight gain, B12 deficiency) in adults with T2D and CHF.

### Chronic Liver Disease

Three studies, 2 of which used retrospective cohort designs^38,49^ and one of which used a prospective cohort design,^50^ evaluated the effect of metformin on KQ 2 outcomes in patients with T2D and CLD (Table 5). Two studies were conducted in Europe^49,50^ and one in the United States.^38^ No studies specifically addressed Veterans. One study reported government funding only,^49^ one reported both government and foundation funding,^38^ and one did not report funding.^50^

Table 5 Effects of Metformin on Mortality in Patients with CLD

Study | Design | Comparison | Outcome (Adjusted analysis)
Ampuero, 2012^49^ | Retrospective cohort n = 82 | Metformin versus no metformin | Rate of all-cause mortality: 7.3% vs 17.1%, p = NR
Nkontchou, 2011^50^ | Prospective cohort n = 100 | Metformin versus no metformin | Rate of all-cause mortality: 7.7% vs 48.6%, p = NR
Zhang, 2014^38^ | Retrospective cohort n = 250 | Metformin continuation versus discontinuation | Survival: 11.8 versus 5.6 years (p<0.0001), HR 0.43 (95% CI 0.27 to 0.82, p = 0.005) Survival subgroup analysis: Child-Pugh class A: HR 0.47 (95% CI 0.27 to 0.82) class B/C: HR 0.46 (95% CI 0.21 to 0.98)

#### All-cause Mortality

All 3 studies evaluated the effect of metformin on all-cause mortality versus non-metformin treatment in adults with T2D and CLD. One study had low ROB^38^ and one had moderate ROB.^49^ The other study^50^ was well-designed in general but was considered to have high ROB with regard to the outcome of all-cause mortality because only unadjusted event rates could be derived from the information presented in the article. In all, these studies involved 432 patients with CLD; in all 3 studies, the entire population had CLD. Individual study sample sizes ranged from 82 to 250 patients. Median follow-up time ranged from about 4.5 to 5.7 years.

All studies focused on patients with CLD with known cirrhosis, as defined by histologic criteria with other adjunctive clinical criteria (ultrasound, biochemical parameters). No studies reported the population's median metformin dose. Mortality was defined based on medical record or administrative data in the 2 retrospective studies,^38,49^ and by every-6-month assessment in the prospective study.^50^ All studies performed statistical adjustment based on baseline population differences between metformin users and nonusers for their primary analyses; however, as above, only all-cause mortality event rates were provided in 2 studies, so incidence was unadjusted.^49,50^

Given the low number of studies and differences in study quality with regard to the outcome of all-cause mortality, quantitative synthesis was not attempted. The study with low ROB found a significantly longer survival associated with metformin therapy (n = 250, HR 0.43, 95% CI 0.24 to 0.78), which was observed regardless of cirrhosis severity (Child-Pugh class A: HR 0.47, 95% CI 0.27 to 0.82; class B/C: HR 0.46, 95% CI 0.21 to 0.98).^38^ Of note, on additional post-hoc subgroup analysis, the beneficial effect of metformin on survival was seen only among patients with cirrhosis secondary to nonalcoholic steatohepatitis (n = 142, HR 0.33, 95% CI 0.17 to 0.63); no statistically significant differences were seen among the relatively small groups of patients with cirrhosis related to alcohol, hepatitis C virus, or hepatitis B virus.

The study with moderate ROB found a trend toward a lower all-cause mortality rate among cirrhotic patients taking metformin compared with nonusers of metformin (n = 82, 7.3% [3/41] versus 17.1% [7/41], p = NR).^49^ In the study with high ROB, there was likewise an apparently lower all-cause mortality rate among patients taking metformin compared with nonusers (n = 100, 7.7% [2/26] versus 48.6% [36/74], p = NR); however, as above, baseline population differences were present without adjustment.^50^

#### Other Outcomes

No studies were identified that evaluated the effect of metformin on other outcomes of interest (MACE, glycemic control, lipid control, hypoglycemia, weight gain, B12 deficiency) in adults with T2D and CLD.

### Older Adults

Fourteen studies evaluated the effect of metformin in older adults (7 RCTs,^51-57^ 7 observational^58-64^). Most studies were conducted in North America, with the remaining conducted in Europe or across multiple continents. Three large observational studies were conducted using VA data.^58,62,63^ Results are organized by major outcomes, and within outcomes, by RCT then observational studies.

#### All-cause Mortality and Major Adverse Cardiovascular Events

A single large RCT evaluated the effects of metformin compared to other usual care treatments in adults with T2D who were suboptimally controlled on diet or sulfonylurea.^52^ This 1-year trial with moderate ROB randomized 7,200 adults to metformin and 1,200 to non-metformin treatment as directed by their physician. Outcomes were reported in the subgroups <65 years of age and ≥ 65 years of age. In the older subgroup (n = 3,084), all-cause mortality did not differ between metformin and usual care (2.4% vs 2.1%, p = 0.878). The rate of emergent cardiac disorders was identical between groups (5.6%).

Three retrospective cohort studies evaluated the effects of metformin on all-cause mortality^58,63,64^ and one reported effects on a composite measure of acute MI, stroke, or death.^62^ All 4 studies showed lower mortality or a composite of major cardiovascular event and mortality in older adults treated with metformin compared with a sulfonylurea. However, the study conducted in a cohort of older Veterans^63^ found no effect in those who were frail as defined by an ICD-9 code for anemia, fluid electrolyte imbalance, fall, fracture, head injury coagulopathy, or weight loss (Table 6). Rosiglitazone monotherapy (but not combination therapy) was associated with increased CHF (HR 1.32; 95% CI 1.07, 1.63).

Table 6 Effects of Metformin on Mortality or MACE in Older Adults

Study | Design | Comparison | Outcome (Adjusted Analysis)
Bannister, 2014^58^ | Retrospective cohort n = 90,463 | Sulfonylurea versus metformin | Survival Age 64-71: Survival time ratio 0.55 (95% CI 0.47 to 0.65) Age >88: Survival time ratio 0.58 (95% CI 0.54 to 0.63)
Cryer, 2005^52^ | RCT n = 7,200 | Usual care versus metformin | Mortality in subgroup age ≥ 65 years: 2.1% vs 2.4%, p = 0.88
Roumie, 2012^62^ | Retrospective cohort n = 253,690 | Sulfonylurea versus metformin | MACE or mortality HR 1.18 (95% CI 1.09, 1.28) MACE: HR 1.13 (95% CI 1.03, 1.24)
Tzoulaki, 2009^64^ | Retrospective cohort n = 91,521 | Second- generation sulfonylurea versus metformin Rosiglitazone versus metformin | Subgroup age ≥ 65 years: Mortality: HR 1.35 (95% CI 1.28, 1.42) Myocardial infarction: HR 1.22 (95% CI 1.10, 1.35) CHF: HR 1.18 (95% CI 1.10, 1.26) No difference in mortality or myocardial infarction. Increased CHF (HR 1.32, 95%CI 1.07, 1.63) with monotherapy but not in combination with other hypoglycemic drugs
Wang, 2014^63^ | Retrospective cohort n = 2,415 | Metformin versus sulfonylurea | Mortality With frailty: HR 0.92 (95% CI 0.90, 1.31) Without frailty: HR 0.69 (95% CI 0.60, 0.79)

#### Glycemic Control

Six RCTs (1144 patients) evaluated the effects of metformin on glycemic control.^51,53-57^ One trial enrolled patients >70 years of age;^54^ all other trials enrolled or analyzed subgroups of patients ≥65 years of age. In 4 trials, eligible patients had suboptimal glycemic control on a sulfonylurea or metformin monotherapy.^51,54-56^ All but one trial specifically excluded patients with renal disease, and the majority excluded patients with CLD or CHF.^55^ In 4 trials, metformin monotherapy was compared with a sulfonylurea^51,53,56^ or DPP-4 inhibitor monotherapy.^57^ One 2-arm trial^54^ and 3 multi-arm trials^51,53,56^ included a comparison of metformin plus sulfonylurea with sulfonylurea alone. One trial compared a combination of metformin plus a sulfonylurea with pioglitazone plus a sulfonylurea.^55^ Outcomes were assessed at a median of 22 weeks (range: 16 weeks to 18 months). ROB was assessed as low in 5 trials and high in 1 trial, but in 4 studies, results were based on post-hoc subgroup analyses. Appendix F has details on the study characteristics.

Effects of treatment were analyzed differently across trials, and statistical tests were not always reported for between group comparisons (Table 7). However, the differences between metformin and sulfonylurea or DDP-4 inhibitor monotherapy were uniformly small (HbA1c difference ≤0.3% between metformin and comparator groups). Metformin plus a sulfonylurea compared with metformin plus pioglitazone yielded similar reductions in A1c. When metformin was combined with a sulfonylurea and compared to treatment with a sulfonylurea alone,^51,53,54,56^ the combination was associated with greater reductions in A1c in 2 of the 4 trials (range: -0.7 to -1.8 combination versus +0.2 to -1.2 for sulfonylurea monotherapy).

Table 7 Effects of Metformin on A1c in Older Adults—RCTs

Study | Precaution Analysis Sample | Intervention (average dose): Effect on A1c^a^ Comparator (average dose): Effect on A1c
Blonde, 2002^51^ | Age ≥65 n = 65, subgroup | - Metformin (1840mg): A1c change +0.2%; - Glibenclamide (20mg): A1c change -0.1%; - Metformin (1759mg) + Glibenclamide (8.8mg): A1c change -1.5%; - Metformin (1744mg) + Glibenclamide (17.4mg): A1c change -1.8%
Garber, 2002^53^ | Age ≥65 n = 74, subgroup | - Metformin (1324mg): A1c change -0.9%; - Glibenclamide (5.4mg): A1c change -1.2%; - Metformin (568mg) + Glibenclamide (2.8mg): A1c change -1.5%; - Metformin (840mg) + Glibenclamide (4.2mg): A1c change -1.3%
Gregorio, 1999^54^ | Age >70 n = 174, whole sample | - Metformin (1518mg) + Sulfonylurea: A1c mean 8.54 (SE 0.12); - Glibenclamide (13.2mg) or Glycoside (214.7mg): A1c mean 8.58 (SE 0.12)
Hanefeld, 2004^55^ | Age ≥65 n = 169, subgroup | - Metformin + Sulfonylurea (NR): A1c change -1.46 (SE 0.08); - Pioglitazone + Sulfonylurea (NR): A1c change -1.41 (SE 0.09)
Marre, 2002^56^ | Age ≥65 n = 59, subgroup | - Metformin (1660mg): A1c change -0.1%; - Glibenclamide (13.4mg): A1c change +0.2%; - Metformin (1225mg) + Glibenclamide (6.1mg): A1c change -1.3%; - Metformin (170mg)+ Glibenclamide (11.7mg): A1c change -0.7%
Schweizer, 2009^57^ | Age >65 n = 335, whole sample | - Metformin (1500mg): A1c change -0.75%; - Vildagliptin (100mg): A1c change -0.64%

a Average dose is reported for the sample overall; dose for older adult subgroup is not known.

One study used a retrospective cohort design to evaluate the effects of metformin on glycemic control in 2,107 Veterans.^60^ Outcomes were adjusted for multiple demographic and clinical covariates. Twelve-month A1c was similar in metformin and sulfonylurea users overall; no interaction effects were found by age group (<65, 65-75, and >75 years of age).

#### Cholesterol and Weight

Two trials (386 patients) reported the effects of metformin on cholesterol and weight in older adults.^54,55^ A study with low ROB conducted a post-hoc analysis of 212 adults >65 years of age with inadequate control on a sulfonylurea who were randomized to pioglitazone or metformin.^55^ At 52 weeks, the change in LDL cholesterol did not differ significantly between groups, but HDL increased more in the pioglitazone group (pioglitazone 16.77 vs metformin 7.85, p<0.05). More patients in the pioglitazone group gained weight than in the metformin group (4.8% vs 1%, p = NR). One trial with high ROB that enrolled 174 patients >70 years of age compared the addition of metformin to increased doses of a sulfonylurea in patients with A1c ≥95 on sulfonylurea monotherapy.^54^ At 18-month follow-up, LDL decreased significantly and HDL increased significantly for the metformin group. However, treatment differences between groups were not reported. Change in weight differed by less than 1kg between the 2 groups.

#### Adverse Effects: Hypoglycemia, B12

Five RCTs (742 patients)^51,53,55-57^ and a nested case-control study^59^ reported rates of hypoglycemia (Table 8). Definitions of hypoglycemia varied, with some studies requiring fasting plasma glucose below 50mg/dl to 60mg/dl and other studies relying on symptoms. Hypoglycemic events in the RCTs were low except in one study that did not report the definition used for hypoglycemic episodes.^55^ Hypoglycemic events were lower for metformin compared with a sulfonylurea in one of 3 studies,^53^ and did not differ in the single trial comparing metformin with vildagliptin.^55^ In a trial comparing metformin used in combination with a sulfonylurea versus in combination with pioglitazone, hypoglycemic events did not differ between metformin and comparators, but 95% confidence intervals are extremely broad because of the small number of trials and patients enrolled.^57^

Table 8 Effects of Metformin on Hypoglycemic Events in Older Adults

Study | Design | Comparison | Hypoglycemic Outcomes^a^
Blonde, 2002^51^ | RCT n = 65 | Metformin vs sulfonylurea | OR = 2.82 (95% CI, 0.11 to 71.84)^*^
Bodmer, 2009^59^ | Nested case control n = 7,753 | Sulfonylurea vs metformin | OR for age ≥ 65 years = 3.30 (95% CI 2.18 to 5.00)
Garber, 2002^53^ | RCT n = 74 | Metformin vs sulfonylurea | OR 0.08 (95% CI 0.01 to 0.68)^*^
Hanefeld, 2004^55^ | RCT n = 212 | Metformin vs vildagliptin | OR 1.24 (95% CI, 0.57 to 2.73)^*^
Marre, 2002^56^ | RCT n = 59 | Metformin vs sulfonylurea | OR 0.24 (95% CI, 0.01 to 5.17)^*^
Schweizer, 2009^57^ | RCT n = 322 | Metformin + sulfonylurea versus metformin + pioglitazone | OR 5.12 (95% CI 0.24 to 107.51)^*^

a OR and 95% CI calculated from data reported.

The nested case-control study with low ROB used data from the UK-based General Practice Research Database to compare rates of hypoglycemia in current sulfonylurea users with current metformin users.^59^ Overall, 2,025 case subjects with hypoglycemia were compared with 7,728 matched-control subjects; stratified analyses for patients <70 and ≥70 years of age were presented. The risk of hypoglycemia was elevated for sulfonylurea users in those <70 (OR 2.71; 95% CI 2.04 to 3.61) and those ≥70 (OR 3.30; 95% CI 2.18 to 5.00).

A single small, nonrandomized trial compared vitamin B12 (cobalamin) levels in 10 older adults assigned to metformin and 10 controls.^59^ Outcomes were assessed at 3 months' follow-up. Patients assigned to metformin compared with the control group had a significant decrease in total cobalamin levels (-110pM vs -26pM).

### Quality of Evidence for Key Question 2

Studies included for KQ 2 were mostly rated as moderate ROB, with some rated low ROB (Appendix F). Few studies were rated high ROB. Common quality concerns included (1) incomplete accounting for differences in baseline characteristics and confounding by indication, though some studies did use propensity score matching; (2) limited assessment of metformin use throughout the study period (eg, assessment at baseline only without accounting for subsequent metformin discontinuation in the exposed group or initiation in the unexposed group), though some studies did analyze metformin exposure status in ‘intervals’ to account for this concern; (3) incomplete assessment and description of attrition within the study populations; and (4) unblinded outcome assessment. These factors may have contributed to the heterogeneity in our qualitative and quantitative syntheses.

### Summary of Findings

Based on our quantitative syntheses of observational evidence, metformin use is associated with a lower risk of all-cause mortality when compared with non-metformin treatment among patients with medically treated T2D and CKD. High heterogeneity was present on meta-analysis, but appeared to be related to variance in the magnitude of effects that consistently favored metformin. The impact of CKD severity on the apparently beneficial effect of metformin on all-cause mortality is not completely clear based on available data, but limited evidence may indicate less benefit with progressively lower eGFR. Qualitative synthesis of limited observational evidence shows that metformin use may be associated with a lower risk of CHF readmission when compared with nonuse among patients with medically treated T2D and CKD, and with a similar risk of MACE-associated diagnoses.

Based on our quantitative syntheses of observational evidence, metformin use is associated with a lower risk of all-cause mortality when compared with non-metformin treatment among patients with medically treated T2D and CHF. Moderate heterogeneity was present on meta-analysis, but appeared to be related to variance in the magnitude of effects that consistently favored metformin. The impact of CHF severity on the apparently beneficial effect of metformin on all-cause mortality is unclear. Based on our quantitative syntheses of observational evidence, metformin use is associated with a lower risk of CHF readmission when compared with nonuse among patients with medically treated T2D and CHF, though high heterogeneity was present. A quantitative synthesis of available data showed no difference in the risk of cardiovascular mortality with metformin use versus non-metformin treatment.

Limited evidence is available regarding all-cause mortality in CLD, but qualitative synthesis of available evidence suggests that metformin may be beneficial in this population.

Data on the effects of metformin in older adults are limited, with most coming from subgroup analyses of randomized trials and in samples without coexisting CHF, CKD, or CLD. Qualitative synthesis of available data indicates that metformin use does not increase all-cause mortality or MACE relative to nonuse. Qualitative synthesis of available data suggests that metformin monotherapy provides similar reductions in HbA1c as sulfonylurea or vildagliptin monotherapy does. Qualitative synthesis of available data indicates that metformin use is not associated with higher rates of hypoglycemia than non-metformin treatment.

No evidence was identified regarding the effects of metformin on glycemic control, lipid control, weight, hypoglycemia, or vitamin B12 deficiency among patients with medically treated T2D and CKD, CHF, or CLD; additionally, no evidence was identified for MACE in CLD. Likewise, the impact of CHF severity, CLD severity, and increasing older age on the effects of metformin use is unclear based on available evidence.