# METHODS

## TOPIC DEVELOPMENT

The key questions (KQs) for this systematic review were developed after a topic refinement process that included a preliminary review of published, peer-reviewed literature; consultation with internal partners and investigators; and consultation with content experts and key VA stakeholders.

The final KQs were:

KQ 1. For patients with type 2 diabetes and an apparent contraindication/precaution to metformin use (eg, renal insufficiency, congestive heart failure, chronic liver disease, or older age):

a. What is the rate of lactic acidosis in patients taking metformin?
b. How does the rate of lactic acidosis in patients taking metformin compare with the rate in patients taking other hypoglycemics?

KQ 2. For patients with type 2 diabetes and an apparent contraindication/precaution to metformin use, what are the potential benefits and harms (other than lactic acidosis) of continued treatment with metformin?

We followed a standard protocol for this review, and each step was pilot-tested to train and calibrate study investigators. The PROSPERO registration number is CRD42016027708.

## SEARCH STRATEGY

In consultation with an expert librarian, we conducted searches of MEDLINE (via PubMed), the Cochrane Central Register of Controlled Trials (KQ 2 only), Embase, and the International Pharmaceutical Abstracts in November 2015. The exact search strategies are in Appendix B. We also searched ClinicalTrials.gov for relevant completed and ongoing studies.

We also evaluated the reference lists of systematic or nonsystematic reviews and queried Bristol-Myers Squibb, the manufacturer of Glucophage (branded formulation of metformin), for relevant studies. We used a combination of MeSH keywords and selected free-text terms to search titles and abstracts. All citations were imported into 2 electronic databases (for referencing, EndNote^®^ Version X7, Thomson Reuters, Philadelphia, PA; for data abstraction, DistillerSR; Evidence Partners Inc., Manotick, ON, Canada).

## STUDY SELECTION

Using prespecified inclusion/exclusion criteria (Table 2), titles and abstracts of RCTs identified through our search were reviewed by 2 reviewers for potential relevance to the KQs. Articles included by either reviewer underwent full-text screening. At the full-text screening stage, 2 independent reviewers were required to agree on a final inclusion/exclusion decision. Disagreements were resolved by discussion or by a third investigator. Of note, prior to excluding any potentially eligible study whose primary analysis did not address a population with a metformin contraindication or precaution, we specifically examined the full text for analyses of relevant subgroups. Articles meeting eligibility criteria were included for data abstraction.

Table 2 Inclusion and Exclusion Criteria

Study Characteristic | Inclusion/Exclusion Criteria
Population | Adults (≥18 years of age) with T2D (using criteria valid at the time of the study) and one of the following contraindications/precautions to metformin use: CKD, CHF, CLD, or older age as defined by authors of the primary study. Exclusions:; - Mixed samples where less than 80% have one or more of the specified contraindications/precautions, and results are not reported by subgroup.; - Studies where less than 80% of the sample has T2D. The rationale is that relatively homogeneous samples of the population of interest are required to evaluate metformin effects.; - Samples with prediabetes or metabolic syndrome, gestational diabetes mellitus, acute kidney injury in the absence of CKD, end-stage renal disease on hemodialysis, and contrast exposure (eg, contrast-enhanced imaging procedures). CKD may be defined as an elevated creatinine or eGFR <60 mL/min/1.73m^2^; microalbuminuria alone is not considered CKD for the purposes of this review.
Interventions | Metformin use alone or in combination with other glucose-lowering treatment. Exclusion: Phenformin
Comparators | - KQ 1a: None, or any inactive control or active comparator; - KQ 1b and KQ 2: Non-metformin oral or injectable hypoglycemic medication(s) in the presence of a traditional contraindication or precaution to metformin use; Exclusion: Studies that did not allow evaluation of the effect of metformin (eg, studies that compared metformin plus a hypoglycemic medication to metformin plus a different hypoglycemic medication)
Outcomes | - KQ 1a and 1b: Incidence of fatal and nonfatal LA or metformin-associated LA^a^; - KQ 2: Benefits evaluated include glycemic control (ie, A1c), lipid control, major adverse cardiovascular events (MACE) (eg, MI, CHF hospitalization), cardiovascular-related mortality, and all-cause mortality; harms included hypoglycemia and weight gain; Exclusion: Studies that reported only metformin clearance, metformin levels, or lactate levels without one of the specified outcomes of interest
Timing | Studies reporting outcomes at ≥28 days (approximately 1 month) following initiation of metformin or switching to another medication
Setting | Outpatient or population-based. Studies that identified hospitalized patients with metformin-associated LA and were able to estimate a rate based on outpatient or population-based samples were eligible.
Study design | - KQ 1a: Clinical trials, prospective and retrospective cohort studies, and pharmacovigilance studies. Excluded were case reports, case-series, and cross-sectional studies because such studies cannot provide a rate of LA.; - KQ 1b: Clinical trials, comparative prospective and retrospective cohort studies, case-control studies, and pharmacovigilance studies. Excluded were case reports, case-series, and cross-sectional studies.; - KQ 2: RCTs, nonrandomized clinical trials, and comparative prospective and retrospective cohort studies
Publication type | Full publications in English-language, peer-reviewed journals Exclusions: Meeting abstracts, letters, editorials, and dissertations
Limits | Studies were limited to the 34 countries that are part of the Organization for Economic Cooperation and Development.^17^ The rationale is to limit to countries where T2D is more prevalent and the general medical care is similar to that in United States. For KQ 1a and KQ 1b, the search was limited to 2009 through the present. For KQ 2, we searched from 1994, the year that metformin was approved by the FDA, through the present. A high-quality Cochrane review (search date October 2009^16^) included all clinical trials in patients with T2D and all observational cohort studies evaluating ≥1 month of metformin use. Outcomes were death due to LA, nonfatal LA, and blood lactate levels. Other relevant reviews^13,18^ have even more recent searches.

a LA is defined as blood lactate concentration >45mg/dl or 5.0mEq/L, decreased blood pH, and electrolyte disturbances with an increased anion gap. Metformin-associated LA is defined as meeting the definition for LA plus either (a) elevated metformin level or (b) investigator judgment that LA is metformin-induced. We abstracted information to determine if outcomes conformed or deviated from these definitions.

Abbreviations: CHF = congestive heart failure; CKD = chronic kidney disease; CLD-chronic liver disease; eGFR = estimated glomerular filtration rate; LA = lactic acidosis; MACE = major adverse cardiovascular event; MI = myocardial infarction; RCT = randomized controlled trial; T2D = type 2 diabetes

## DATA ABSTRACTION

Data from published reports were abstracted into a customized DistillerSR database by one reviewer and overread by a second reviewer. Disagreements were resolved by discussion or by a third investigator. Key characteristics abstracted were patient descriptors (including age, sex, race, and specific contraindication/precaution to metformin), setting, metformin dose, cointerventions (eg, other hypoglycemics), comparator, and outcomes which we selected in conjunction with our stakeholders and technical expert panel. For observational studies, we abstracted unadjusted and adjusted outcomes. Other key information included definitions related to contraindications/precautions (eg, definition of CKD and methods for determining CKD/estimating eGFR such as the Modification of Diet in Renal Disease formula^19^ or the Cockcroft-Gault formula^20^). We treated multiple publications from a single study as a single data point, prioritizing the longest-term, most complete, and most appropriately analyzed results. When critical data were missing or unclear in published reports, we requested supplemental data from manuscript authors. Key features relevant to applicability included the match between the sample and target populations (eg, metformin contraindication/precaution, age, concurrent treatments, or Veteran status).

## QUALITY ASSESSMENT

Quality assessment was done independently by 2 investigators. Disagreements were resolved by consensus between the 2 investigators or, when needed, by arbitration by a third investigator.

We used the Cochrane Risk of Bias tool for RCTs^21^ and the key quality criteria described in the Agency for Healthcare Research and Quality's (AHRQ's) Methods Guide for Effectiveness and Comparative Effectiveness Reviews,^22^ adapted to this specific topic and customized to observational studies.^23^ For RCTs, these criteria are adequacy of randomization and allocation concealment; blinding of participants, personnel, and outcomes assessment; whether incomplete data were addressed appropriately; selective reporting, and other bias. We assigned a summary risk of bias score (low, unclear, or high) to individual studies (Appendix C). For observational studies, we used a tool customized to this project that addresses risk of bias from selection, performance, attrition, detection, and selective outcome reporting (Appendix D).^24^

## DATA SYNTHESIS

We summarized the primary literature using relevant data abstracted from the eligible studies. Summary tables describe the key study characteristics of the included studies: metformin contraindication/precaution (including severity such as CKD stage), patient demographics (including age), and details of the intervention and comparator. When necessary,^25,26,25,26^ relevant hazard ratios (HRs) with the same reference group were pooled in a weighted fashion based on the subject counts in each category, incorporating an approximation of the correlation resulting from the shared reference. In the absence of a reported HR,^27^ we estimated the HR and variance from the reported frequencies and odds ratio (OR) using an established approach.^28^ We then determined the feasibility of completing a quantitative synthesis (ie, meta-analysis) to estimate summary effects. For all analyses, we analyzed RCTs separately from observational studies.^29^ We aggregated outcomes when there were at least 3 studies with the same outcome, based on the rationale that one or 2 studies do not provide adequate evidence for summary effects. Analyses were conducted separately for patients with different contraindications or precautions to metformin (eg, CKD vs CHF), using rates adjusted for potential confounders. We planned to conduct subgroup analyses by severity of contraindication/precaution (eg, CKD stage), by single (metformin monotherapy) versus combined treatment (eg, metformin plus other hypoglycemics with or without metformin), and by comparator (lifestyle or placebo vs other hypoglycemics). However, there were too few studies to support the planned subgroup analyses.

Studies reported dichotomous outcomes (eg, LA, mortality, hypoglycemic events) and continuous outcomes (eg, A1c, weight, lipid values). Quantitative synthesis was feasible only for mortality and major adverse cardiovascular event (MACE) outcomes. These outcomes were combined using a random-effects model to generate summary hazard ratios. For analyses with few (n<20) studies, we used the Knapp Hartung approach to adjust the standard errors of the estimated coefficients.^30,31^ Sensitivity analyses omitted studies with severe disease (eg, eGFR < 30ml/min/1.73m^2^. We evaluated statistical heterogeneity using visual inspection and Cochran's Q and I^2^ statistics. Publication bias was assessed using funnel plots (when there were >10 studies in an analysis).

When quantitative synthesis was not feasible, we analyzed the data qualitatively. We gave more weight to the evidence from higher-quality studies with more precise estimates of effect. A qualitative synthesis focuses on documenting and identifying patterns in efficacy and safety of the interventions across conditions and outcome categories. We analyzed potential reasons for inconsistency in treatment effects across studies by evaluating differences in the study population, intervention, comparator, and outcome definitions.

## RATING THE BODY OF EVIDENCE

Strength of evidence (SOE) was assessed using the approach described in the Agency for Healthcare Research and Quality (AHRQ)'s Methods Guide.^22^ We limited Grading of Recommendations Assessment, Development and Evaluation (GRADE) ratings^32^ to those outcomes identified by the stakeholders and technical expert panel as critical to decision making. These included nonfatal and fatal LA and mortality. In brief, this approach assesses 4 domains: risk of bias, consistency, directness, and precision. Additional domains were used when appropriate and included coherence, dose-response association, impact of plausible residual confounders, strength of association (magnitude of effect), and publication bias. These domains were considered qualitatively, and a summary rating was assigned after discussion by 2 investigators as high, moderate, or low strength of evidence. In some cases, high, moderate, or low ratings were impossible or imprudent to make. In these situations, a grade of insufficient was assigned. This 4-level rating scale consists of the following definitions:

- High—We are confident that the true effect lies close to the estimate of effect.
- Moderate—We are moderately confident of the effect estimate: The true effect is likely to be close to the estimate of effect, but there is a possibility that it is substantially different.
- Low—Our confidence in the effect estimate is limited: The true effect may be substantially different from the estimate of the effect.
- Insufficient—We have very little confidence in the effect estimate: The true effect is likely to be substantially different from the estimate of effect.

## PEER REVIEW

A draft of this report was reviewed by technical experts and clinical leadership. A transcript of their comments and our responses is provided in Appendix E.