# INTRODUCTION

Metformin is a biguanide oral hypoglycemic used primarily for treating type 2 diabetes mellitus (T2D). Evidence suggests that, in addition to improving glycemic control, metformin is associated with improved all-cause and cardiovascular mortality^1^ and decreased risk of some cancers (eg, breast cancer).^2^ Despite the potential benefits, since metformin was introduced in the United States in the mid-1990s, clinicians have been advised to exercise caution in prescribing the drug to individuals with certain comorbidities due to perceived risks of serious side effects, including LA. Lactic acidosis (LA) is defined as blood lactate concentration >45mg/dl (5.0mEq/L), decreased blood pH, and electrolyte disturbances with an increased anion gap. It may result from lactate overproduction because of inadequate tissue oxygen delivery or without overt tissue hypoperfusion. The LA type classifications are explained in Table 1.

Table 1 Lactic Acidosis Type Classification^3^

Type A-LA: Clinical Evidence of Inadequate Tissue Oxygen Delivery
- Anaerobic muscular activity (eg, sprinting, generalized convulsions); - Tissue hypoperfusion (eg, shock: septic, cardiogenic, or hypovolemic; hypotension; cardiac arrest; acute heart failure; regional hypoperfusion, especially mesenteric ischemia; malaria); - Reduced tissue oxygen delivery or utilization (eg, hypoxemia, carbon monoxide poisoning, severe anemia)
Type B-LA: No Clinical Evidence of Inadequate Tissue Oxygen Delivery
- Type B1: Associated with underlying diseases (eg, ketoacidosis, leukemia, lymphoma, AIDS); - Type B2: Associated with drugs and toxins (eg, phenformin, cyanide, beta-agonists, methanol, nitroprusside infusion, ethanol intoxication in chronic alcoholics, antiretroviral drugs); - Type B3: Associated with inborn errors of metabolism (eg, congenital forms of LA with various enzyme defects such as pyruvate dehydrogenase deficiency)

Note: Table does not include all causes of LA.

Among the most serious side effects of metformin is metformin-associated LA, which is a rare (approximately 0.03 cases per 1000 person-years) but potentially highly fatal type B-LA.^4^ Metformin is excreted through the kidneys, and most cases of metformin-associated LA have occurred in the setting of inappropriate dosing, significant kidney impairment, sepsis, hypovolemia, excess alcohol intake, hepatic insufficiency, age greater than 80 years, or acute/decompensated congestive heart failure (CHF).^5,6^ As such, the FDA specifies chronic kidney disease (CKD) with low estimated glomerular filtration rate (eGFR) as a contraindication to metformin use, and it lists acute or unstable CHF, older age, and hepatic impairment as precautions for use.^7,8^ Despite these warnings, there are efforts to expand the use of metformin, and currently more than 50% of metformin users may have an ongoing contraindication or precaution for its use.^9,10^

In 2006, the FDA relaxed its warning regarding CHF and metformin use and removed acute or unstable CHF as a contraindication. More recently, in April 2016, the definition of CKD used by the FDA in the boxed warning was modified (Appendix A).^11^ Historically, metformin use was to be avoided in individuals with a serum creatinine ≥1.5mg/dL for men and ≥1.4 mg/dL for women. Serum creatinine is known to be a poor marker of kidney function.^12^ Consequently, this guideline discouraged use of metformin in many individuals with relatively normal kidney function. Therefore, the kidney function cutoff was revised to an eGFR of 45 mL/min/1.73m^2^ if renal function is monitored every 3 months to 6 months, but still contraindicated if eGFR is <30 mL/min/1.73m^2^, consistent with recent clinical guidelines for metformin use and best practices for estimating kidney function.^11,13,14^ An estimated one million additional patients became eligible to use metformin as a result of this change.^15^

Recent literature highlights the rarity of metformin-associated LA and supports the cautious expansion of metformin use. Most notably, a 2010 Cochrane systematic review found no association between metformin use and fatal or nonfatal LA,^16^ and a 2014 systematic review found the incidence of LA among metformin users to be indistinguishable from background population rates, ranging from approximately 3 per 100,000 person-years to 10 per 100,000 person-years.^5^ Yet there remain uncertainties regarding metformin's appropriate use, and the benefit relative to the harm in populations with CKD, CHF, hepatic impairment (eg, chronic liver disease), and older age are not well understood. For this reason, we conducted a systematic review and meta-analysis in order to determine (1) the rates of LA associated with metformin use in patients with T2D and (2) the benefits and harms of metformin use in the presence of traditional contraindications or precautions.