# APPENDIX G RESULTS FOR OLDER ADULTS BY STUDY DESIGN

KQ 2 Older Adults—Study Characteristics of RCTs

Study Country Funding | T2D Condition Age in Years (N) | Other Precautions Excluded | Metformin Dose Comparator Dose | Outcome Definition Reporting | Exposure Duration | ROB
Blonde, 2002^51^ USA Industry | Diagnosis by clinician, laboratory value (A1c remains ≥7.4% with diet, exercise, sulfonylurea) ≥65 subgroup (134) | Liver disease, renal disease, heart failure | Metformin: 500-2000mg Glibenclamide: 2.5mg or 5.0mg | A1c: laboratory value Hypoglycemia: blood sugar <60 mg/dl | 16 weeks | Low
Cryer, 2005^52^ USA Industry | Diagnosis by clinician (“suboptimal control” on diet or sulfonylurea) ≥65 | Abnormal renal or liver function | Metformin: 500-2500mg Usual care: any nonmetformin medication | LA: medical record MACE: medical record Mortality: medical record | 1 year | Mod
Garber, 2002^53^ USA Industry | Diagnosis by clinician, laboratory value (A1c remains >7% with diet, exercise) ≥65 subgroup (159) | Abnormal renal, liver function | Metformin: 500-2000mg Glibenclamide: 2.5mg or 5.0 mg | A1c: laboratory value Hypoglycemia: glucose <50 mg/dl or <100 if on metformin | 20 weeks | Low
Gregorio,1999^54^ Italy NR | Diagnosis by clinician (A1c remains ≥9% with sulfonylurea) >70 (174) | Abnormal liver function, respiratory or heart failure, Creatinine >1 or CrCl<100 ml/min/m2 | Metformin: NR Sulfonylurea: increased dose (exact dose NR) | Weight: clinical scale A1c, LDL, HDL, total cholesterol: laboratory values | 18 months | High
Hanefeld, 2004^55^ Europe, Canada Foundation, Industry | Diagnosis by clinician, laboratory value (A1c remains 7.55-11% on sulfonylurea) >65 subgroup (212) | History of MI, TIA, or stroke in prior 6 months; symptomatic CHF | Metformin + sulfonylurea: 500-2500mg/dl Pioglitazone + sulfonylurea: NR | Weight: clinical scale A1c, LDL, hypoglycemia: laboratory value | 52 weeks | Low
Marre, 2002^56^ Europe Industry | Diagnosis by laboratory value (FPG ≥126 on metformin, diet & exercise) ≥65 subgroup (130) | Renal disease, hepatic dysfunction, severe respiratory disease, acute heart failure, MI | Metformin: 500-2000mg Glibenclamide: 2.5mg or 5.0 mg | A1c: laboratory value Hypoglycemia: glucose <50 mg/dl or <100 if on metformin | 16 weeks | Low
Schweizer, 2009^57^ Americas, Asia, Europe Industry | Diagnosis by clinician plus laboratory value (A1c 7%-9% off hypoglycemic) ≥65 (335) | CHF requiring medication; liver disease, renal disease | Metformin: 500-1500mg Vildagliptin: 100mg | A1c: laboratory value Hypoglycemia: glucose <60 mg/dL | 24 weeks | Low

Abbreviations: A1c = glycated hemoglobin; CHF = congestive heart failure; FPG = fasting plasma glucose; HDL = high-density lipoprotein; LA = lactic acidosis; LDL = low-density lipoprotein; MACE = major adverse cardiac event; MI = myocardial infarction; NR = not reported; Rx = prescription; T2D = type 2 diabetes; TIA = transient ischemic attack

KQ 2 Older Adults—Study Characteristics of Observational Studies

Study Design Country Funding | T2D Condition Exclusions Age in Years (N) | Metformin Dose Comparator Dose | Outcome | Exposure Duration | Statistical Adjustment | ROB
Bodmer, 2008^59^ Nested case control UK Industry | Oral Rx Exclusions: T1D ≥70 (50,048) | Metformin: NR Sulfonylurea: NR | LA, hypoglycemia leading to emergency department visit or death | NR | Use of sulfonylureas, other oral antidiabetic medications, insulin, BMI, smoking, comorbidities, other medications | Low
Bannister, 2014^58^ Retrospective cohort UK Industry | Diagnosis by clinician Exclusions: None >70 (90,463) | Metformin: NR Sulfonylurea: NR | All-cause mortality | Mean 2.8 years | Age, comorbidity index, sex, smoking status, medications | Mod
Huizinga, 2010^60^ Retrospective cohort USA Government | Oral Rx Exclusions: CHF, CKD, liver disease 65-75, >75 years (2096-2484) | Metformin: NR Sulfonylurea: NR | A1c, BMI | 1 year | Age, sex, race, BMI, medications, outpatient visits, hospitalizations, psychiatric comorbidities | Mod
Leung, 2010^61^ Prospective cohort Canada NR | Diagnosis by clinician Exclusions: NR 67-91 (20) | Metformin: NR No metformin | Vitamin B12 | 3 months | None | High
Roumie, 2012^62^ Retrospective cohort USA Government | Diagnosis by ICD code, Rx, laboratory values Exclusions: None ≥65 (253,690) | Metformin: NR Sulfonylurea: NR | Acute MI, stroke or death Acute MI or stroke | Metformin: median 0.78 years Sulfonylurea: median 0.61 years | Age, sex, race, HbA1c/other clinical variables, health care utilization, smoking, medications, comorbidities | Low
Tzoulaki, 2009^64^ Retrospective cohort UK Not funded | T2DM: diagnosis by ICD code Exclusion: patients not taking oral antidiabetic drugs, or patients taking insulin >65 (91,521) | Metformin: NR Sulfonylurea: NR Thiazolidinedione: NR | MACE; mortality | Metformin: median: 5.59 years Sulfonylurea: median 8.5 years (first generation), 6.6 years (second generation) Thiazolidinedione: median 6.7 years | Sex, BMI, smoking SBP, other laboratory variables (eg, HbA1c), duration of diabetes, stratified by year and age quartiles at treatment; comorbidities, other medications, complications from diabetes | Low
Wang, 2014^63^ USA Government Retrospective cohort | Diagnosis by ICD code for T2D and oral Rx Exclusions: CKD, liver disease 65-90 (2415) | Metformin: NR Sulfonylurea: NR | All-cause mortality | ≥24 weeks | Age, race/ethnicity, diabetes duration, comorbidity score, statin use, smoking, BMI, LDL, A1c | Mod

Abbreviations: BMI = body mass index; CHF = congestive heart failure; CKD = chronic kidney disease; eGFR = estimated glomerular filtration rate; HbA1c = glycated hemoglobin; ICD-9 = International Classification of Diseases-9; LA = lactic acidosis; LDL = low-density lipoprotein; MACE = major adverse cardiac event; Mod = moderate; NR = not reported; Rx = prescription; SBP = systolic blood pressure; T1D- type 1 diabetes; T2D = type 2 diabetes