# APPENDIX F STUDY CHARACTERISTICS TABLES

Table 1 KQ 1 Study Characteristics by Condition

Study Design Country Funding | Condition Definitions | Metformin Use Dose Comparator^a^ | Outcome Definition Reporting | Exposure Duration | Statistical Adjustment | ROB
Chronic kidney disease (CKD)
Becquemont, 2015^39^ Prospective cohort France NR KQ 1a only | T2D: diagnosis, Rx CKD: eGFR category (based on whether metformin was adapted to eGFR) | Metformin use assessed prospectively Median dose 2000mg daily (IQR 1700-2550) Comparator: NA | LA: not specified Event rate | Mean 3 years No time-adjusted analysis | Age, eGFR | High
Ekstrom 2012^40^ Retrospective cohort, population-based Sweden Government KQ 1a and 1b | T2D: diagnosis, Rx CKD: eGFR category (45-60, 30-45) | 12 months use of metformin Median dose 1100-1900mg Comparator: 12 months use of other oral antidiabetic agent (dose NR) | LA or serious infection: defined by diagnostic code Event rate, hazard ratio | Mean 3.9 years No time-adjusted analysis | Age, sex, HbA1c, smoking, BMI, eGFR, comorbidities, medications | Mod
Eppenga, 2014^34^ Retrospective cohort, population-based Great Britain Government, Industry KQ 1a and 1b | T2D: Rx CKD: eGFR category >60, 45-59, 30-44, <30 | Current metformin use Stratified by yearly or daily dose Comparator: never use of metformin but current use of other NIAD | LA: defined by Read code or lactate >5 mmol/L Event rate, hazard ratio | Mean 4.3 years Time-adjusted analysis using intervals | Age, sex, BMI, CHF, medications | Mod
Richy, 2014^33^ Retrospective cohort, population-based Great Britain Industry KQ 1a only | T2D: diagnosis, Rx CKD: eGFR category >90, >60-90, >30-60, <30 | Any metformin Rx Dose NR Comparator: NA | LA: defined by ICD-9, fatal LA if death within 14 days Incidence rate | Mean 4.35 years Time-adjusted analysis using person-years | None | High
Congestive heart failure (CHF)
Andersson, 2010^25^ Retrospective cohort, population-based Denmark Government KQ 1a and 1b | T2D: Rx CHF: First CHF hospitalization based on diagnostic codes | Metformin use based on Rx records Dose NR Comparator: multiple comparator arms | LA: defined by ICD-9 Event rate | Median 844 days Secondary time-adjusted analysis based on individual drug coverage | Year, age, sex, Charlson, diabetes complications, medications (but NA here) | Mod
Romero, 2013^35^ Prospective cohort, community-based Spain Government KQ 1a and 1b | T2D: diagnosis, Rx, laboratory values CHF: Framingham criteria | Metformin use based on Rx records Dose NR Comparator: no metformin use (dose NR) | LA: NR Event rate | Median 56.9 months Time-adjusted analysis using person-years | Multivariate analysis (but NA here) | Low
Liver disease
Zhang, 2014^38^ Retrospective cohort, population-based USA Government KQ 1a and 1b | T2D: diagnosis by clinician, Rx, self-report, or laboratory values Liver disease: biopsy-proven cirrhosis with additional clinical evaluation | Continuation or discontinuation of metformin after cirrhosis (defined as cessation of metformin within 3 months after diagnosis) Dose NR Comparator: discontinued metformin use | LA: categorical Mortality: 10-year survival; categorical | 5-10 years | Age, sex, albumin, MELD score, AFP level, etiology of cirrhosis | Low
Older adults
Ito, 2011^36^ Pharmacovigilance Japan NR KQ 1a only | Rx, laboratory Exclusion: receiving unknown combination drugs, poor drug compliance, unclear initiation date of metformin, surgery | Metformin: 250mg, 500mg, 750mg, 1000mg (majority 750mg) Comparator: NA | LA: categorical; LA level above upper limit of reference values (2.28 mmol/L) | 1 year after initiation of metformin | NR | High
Sterner, 2012^37^ Retrospective Sweden Not funded KQ 1a only | Diagnosis: ICD code or NR eGFR using CKD-EPI formula Age categories in years: 60-69, 70-79, 80-89, ≥90 Median age 67 years | Metformin: dose NR No metformin: dose NR | Lactic acidosis measured by lactate levels >5mmol/L and serum pH <7.35 | 2 years | NR | High

a Comparator applies only to KQ 1b.

Abbreviations: AFP = alpha-fetoprotein; BMI = body mass index; CHF = congestive heart failure; CKD = chronic kidney disease; eGFR = estimated glomerular filtration rate; HbA1c = glycated hemoglobin; ICD-9 = International Classification of Diseases-9; IQR = interquartile range; KQ = key question; LA = lactic acidosis; MACE = major adverse cardiac event; MELD = model for end-stage liver disease; Mod = moderate; NA = not applicable; NIAD = noninsulin antidiabetic drug; NR = not reported; Rx = prescription; T2D = type 2 diabetes

Table 2 KQ 2 Study Characteristics by Condition

Study Design Country Funding | Condition Definitions | Metformin Use Dose Comparator | Outcome Definition Reporting | Exposure Duration | Statistical Adjustment | ROB
Chronic kidney disease (CKD)
Aguilar, 2011^41^ Retrospective cohort, outpatient-based USA Government | T2D: diagnosis, Rx CKD: eGFR based on most recent serum creatinine | Metformin Rx 90 days pre-index to 30 days post-index date Dose NR Comparator: no metformin Rx | All-cause mortality: time to death over 2 year follow-up after index visit Hazard ratio | 2 years complete follow-up No time-adjusted analysis | Propensity score matching | Low
Ekstrom, 2012^40^ Retrospective cohort, population-based Sweden Government | T2D: diagnosis, Rx CKD: eGFR category (45-60, 30-45) | 12 months use of metformin Median dose 1100-1900mg Comparator: 12 months continuous use or use of other oral antidiabetic agent | All-cause mortality: by death registry MACE: diagnosis of included conditions Event rate, hazard ratio | Mean 3.9 years No time-adjusted analysis | Age, sex, HbA1c, smoking, BMI, eGFR, comorbidities, medications | Mod
Masoudi, 2005^42^ Retrospective cohort, population-based USA Government | T2D: diagnosis by medical record, Rx CKD: serum creatinine >1.5 mg/dL | Metformin use after index hospitalization Dose NR Comp: no metformin or pioglitazone | All-cause mortality: time from index hospitalization to death or readmission for heart failure MACE Hazard ratio | Described as 1 year No time-adjusted analysis | Year, provider, hospital, baseline medical factors with p<0.05 | Mod
Morgan, 2014^43^ Retrospective cohort, population-based UK Industry | T2D: incident diagnosis based on codes and/or Rx Hypoglycemia: NR CKD: clinical diagnosis or baseline serum creatinine >132 or 123 μmol/l (male, female) | New metformin Rx from medical records Dose NR Comparator: new sulfonylurea Rx | All-cause mortality: determined by date of death in medical record Hazard ratio | Metformin: 2.9 years Sulfonylurea: 3.1 years No time-adjusted analysis | All baseline factors with difference, p<0.2 | Low
Roussel, 2010^44^ Prospective cohort, outpatient-based Multiple countries Foundation, Industry | T2D: Rx CKD: eGFR based on baseline serum creatinine | Metformin use at baseline assessment Dose NR Comparator: no metformin use | All-cause mortality: per 2-year follow-up assessment Event rate, hazard ratio | Mean 20.8 and 20.9 months for metformin users, nonusers No time-adjusted analysis | All baseline factors with difference, p<0.2 and propensity score | Mod
Weir, 2011^74^ Nested case-control Canada Government | T2D: ICD code and medical records CKD: impaired eGFR based on serum creatinine values | Metformin: given at all eGFR levels; dose NR Comparator: Insulin, Glyburide: Dose NR | Hypoglycemia: by ICD-9 codes Odds ratio | 120-day interval immediately preceding index date to identify DM prescriptions | Hypoglycemic events, comorbidities, recent hospitalization, medications, internist visits | Mod
Congestive heart failure (CHF)
Aguilar, 2011^41^ Retrospective cohort, outpatient-based USA Government | T2D: diagnosis and/or Rx for diabetes medication CHF: diagnosis by ICD-9 codes | Metformin Rx 90 days pre-index to 30 days post-index date Dose NR Comparator: no metformin | All-cause mortality: time to death over 2 years after index visit MACE Event rate, hazard ratio | 2 years complete follow-up No time-adjusted analysis | Propensity score matching | Low
Andersson, 2010^25^ Retrospective cohort, population-based Denmark Government | T2D: Rx CHF: first CHF hospitalization based on diagnostic codes | Metformin use based on Rx records Dose NR Comparator: multiple comparator arms | All-cause mortality: determined from death registry MACE Event rate, hazard ratio | Median 844 days Secondary time-adjusted analysis based on individual drug coverage | Year, age, sex, comorbidities, diabetes complications, medications | Mod
Eurich, 2005^26^ Retrospective cohort, population-based Canada Government, Foundation | T2D: Rx for oral diabetes medication CHF: First CHF hospitalization by ICD-9 codes | Metformin alone or in combination Dose NR Comp: sulfonylurea alone | All-cause mortality: method of determination NR at 1 year and follow-up MACE Event rate, hazard ratio | Mean 2.5 years Time adjustment not needed per design | CDS, number visits, medications, propensity score analysis | Mod
Evans, 2010^45^ Retrospective cohort, population-based Scotland Foundation and private business | T2D: diagnosis or Rx medication 1994-2003 CHF: first hospitalization with ICD codes | Rx for metformin or metformin + sulfonylurea Dose NR Comparator: sulfonylurea alone | All-cause mortality: by death certificate records Odds ratio | Range: 1-9 years (mean NR) No time-adjusted analysis | All factors with univariate p<0.05 | Mod
Inzucchi, 2005^46^ Retrospective cohort USA Government | T2D: Clinician diagnosis, medication records CHF: first CHF hospitalization based on diagnostic codes | Metformin alone or Metformin and Thiazolidinedione Dose: NR Comparator: No insulin sensitizer | Mortality: all-cause mortality with impaired LVEF, 1 year mortality, readmission for heart failure, MI. MACE Hazard ratio | Reported at 1 year | Age, sex, race; cardiac and noncardiac comorbidities, clinical characteristics at admission (eg, SBP), sample frame for index hospitalization | Low
Masoudi, 2005^42^ Retrospective cohort, population-based USA Government | T2D: diagnosis by medical record, Rx CHF: ICD-9 codes at index hospitalization | Metformin use after index hospitalization Dose NR Comparator: no metformin | All-cause mortality: Medicare data (time from index date to death) MACE Hazard ratio | Reported as 1 year, no mean No time-adjusted analysis | Year, provider, hospital, baseline medical factors with difference, p<0.05 | Mod
Romero, 2013^35^ Prospective cohort, community-based Spain Government | T2D: diagnosis, Rx, laboratory values CHF: Framingham criteria | Metformin use based on Rx records Dose NR Comparator: no metformin use (dose NR) | All-cause mortality: determined by medical records MACE Event rate, hazard ratio | Median 56.9 months Time-adjusted analysis using person-years | Multivariate analysis | Low
Roussel, 2010^44^ Prospective cohort, outpatient-based Multiple countries Foundation, Industry | T2D: Rx CHF: means of diagnosis unclear, likely clinical | Metformin use at baseline assessment Dose NR Comparator: no metformin use | All-cause mortality: per 2 year follow-up assessment Event rate, hazard ratio | Mean 20.8 and 20.9 months for metformin users, nonusers No time-adjusted analysis | All baseline factors with difference, p<0.2 and propensity score | Mod
Shah, 2010^47^ Retrospective cohort, outpatient-based USA Government, Foundation | T2D: diagnosis by clinician, medical record, self-report CHF: diagnosis by LVEF ≤40% | Metformin use at first visit Dose NR Comparator: no metformin use | All-cause mortality: determined clinically (not including urgent heart transplant) | Follow-up at 1 year and 2 years No time-adjusted analysis | Age, sex, LVEF, renal function, BMI, diabetes duration, medications | Mod
Tinetti, 2015^48^ Retrospective cohort, population-based USA Government | T2D: diagnosis by medical records CHF: diagnosis by ICD-9 codes or claims data | Metformin Rx Dose NR Comparator: no metformin | All-cause mortality: determined by Medicare vital status file Hazard ratio | Median 24 months Time adjustment analysis | Age, sex, race, income, smoking, medication, insurance, physical and mental function | Mod
Weir, 2014^27^ Retrospective cohort, population-based USA NR | T2D: Rx for oral diabetes medication Hypoglycemia: NR CHF: First CHF hospitalization by ICD-9 codes | Exposure to metformin based on pharmacy claims within 90 days of index event Mean dose NR Comparator: no exposure to metformin | All-cause mortality: U.S. national death index files Event rate, odds ratio | Median 1.4 years Partial time adjustment | Propensity score analysis | Mod
Liver disease
Ampuero, 2012^49^ Retrospective cohort Spain Government | T2D: by clinician Liver biopsy-proven cirrhosis with additional clinical evaluation | Metformin treatment Dose: 0, 20, 50, 100 and 200 mmol/L Comparator: no metformin | All-cause mortality: overall survival rate trend; categorical | Metformin: 39.6 ± 28.3 months Comparator: 45.5 ± 26.5 months | Yes | Mod
Nkontchou, 2011^50^ Prospective cohort France NR | T2D: Rx, laboratory values Liver disease: 1. Biopsy-proven cirrhosis with additional clinical evaluation 2. Presence of anti-HCV antibodies 3. Presence of serum HCV RNA | Metformin treatment Dose NR Comparator: no metformin | All-cause mortality: liver-related death; categorical | Median follow-up of 5.7 years (range 3.8-9.5) | Age, platelet count, BMI, alcohol abuse, diabetes duration | High
Zhang, 2014^38^ Retrospective cohort, population-based USA Government, Foundation | T2D: by clinician, Rx, self-report, or laboratory values Liver biopsy-proven cirrhosis with additional clinical evaluation) | Continuation or discontinuation of metformin after cirrhosis (defined as cessation of metformin within 3 months after diagnosis) Dose NR Comparator: discontinued metformin use | LA: categorical All-cause mortality: 10-year survival; categorical | 5-10 years | Age, sex, albumin, MELD score, AFP level, etiology of cirrhosis | Low

Abbreviations: AFP = alpha-fetoprotein; BMI = body mass index; CHF = congestive heart failure; CKD = chronic kidney disease; eGFR = estimated glomerular filtration rate; HCC = hepatocellular carcinoma; HCV = hepatitis C virus; LA = lactic acidosis; LVEF = left ventricular ejection fraction; MACE = major adverse cardiac event; MELD = model for end-stage liver disease; NA = not applicable; NR = not reported; RNA = ribonucleic acid; Rx = prescription; T2D = type 2 diabetes