# APPENDIX E PEER REVIEW COMMENTS/AUTHOR RESPONSES

Reviewer | Comment | Response
Question 1. Are the objectives, scope, and methods for this review clearly described?
1 | Yes | Acknowledged
3 | Yes | Acknowledged
4 | Yes | Acknowledged
Question 2. Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked?
1 | No | Acknowledged
3 | No | Acknowledged
4 | Yes - A recent meta-analysis examined comparative effectiveness of glucose-lowering agents with respect to CV mortality, as well as several other outcomes: all-cause mortality, serious adverse events, myocardial infarction, stroke, HbA1c level, treatment failure (rescue treatment or lack of efficacy), hypoglycemia, and weight (Palmer et al. Comparison of Clinical Outcomes and Adverse Events Associated With Glucose-Lowering Drugs in Patients With Type 2 Diabetes JAMA July 19, 2016). In that meta-analysis, there were no significant differences in associations between any drug class as monotherapy, dual therapy, or triple therapy with odds of cardiovascular or all-cause mortality (including metformin). The meta-analysis came out after the authors submitted their review, but I recommend that they include this in their discussion and specifically address why their findings were different from the findings of the meta-analysis with respect to CV and all-cause mortality outcomes. | Thank you for identifying this recent review by Palmer et al. We added a discussion of the review's findings and how they relate to our results.
Question 3. Is there any indication of bias in our synthesis of the evidence?
1 | No | Acknowledged
3 | No | Acknowledged
4 | No | Acknowledged
Question 4: Please write additional suggestions or comments below. If applicable, please indicate the page and line numbers from the draft report.
1 | Very useful ESP document, and as usual, very well done. Despite the fact that FDA released new guidance after this was commissioned, the review remains very relevant- and in fact may be even more important as this document states, it is likely that metformin will be used more often in “higher risk” populations. Just a couple of minor thoughts: | Thank you.
1 | 1) “Black Box” on page 6, line 56-57: The correct term would be “boxed warning”. FDA does not recognize the Black Box terminology. Not a big deal if left in. | 1) Thank you for this correction. The wording has been changed as recommended.
1 | 2) Limitations: You might add that most of the studies compared metformin to sulfonylureas and to a lesser extent, TZDs. Both of these drug classes have their issues- and so it might be reasonable to acknowledge that the comparisons do not include the newer anti-diabetic agents. | 2) A statement about the majority of comparisons being to sulfonylureas and thiazolidinediones has been added to limitations.
1 | 3) Likewise- research should make these same comparisons with newer agents. THANKS AGAIN to ESP for doing this review. | 3) A statement about the need for these comparisons has been added to future research.
3 | The review was comprehensive, and appropriately noted that limitations of the observational data literature. | Thank you.
4 | The authors reviewed the use of metformin among patients with relative contraindications or precautions to its use, compared the risk of lactic acidosis among users of metformin versus users of other glucose-lowering agents, and compared other outcomes association with the use of metformin versus other glucose-lowering agents. The review focuses on an important clinical question and is well executed and well written. Specific concerns: | Thank you.
4 | KQ2: Limited data exist with respect to comparative benefits and harms of glucose-lowering agents. Authors have selected several outcomes for evaluation: glycemic control, lipid control, MACE, CV mortality, all-cause mortality, hypoglycemia, and weight gain. I recommend discussing rationale for the selection of these outcomes. What about other outcomes of importance to patients, such as microvascular complication rates, health-related quality of life? I understand there are limited data with respect to these outcomes, but this should not preclude them being included as a key question (which perhaps can't be answered at this time). | Outcomes selected for evaluation were prioritized with input from our stakeholders and Technical Expert Panel. We have added this detail to the Methods section.
4 | Inclusion and exclusion criteria: I agree with the authors' decision to include studies with the outcome of lactic acidosis (high lactate, low pH, and high anion gap). This definition of lactic acidosis should be stated in the text (currently as footnote to Table 2). This is an important point since there are some studies, which examined lactate levels alone; lactate levels are poor surrogates for lactic acidosis. | Acknowledged and thank you. We have added the definition of lactic acidosis to the introduction.
4 | Page 15, lines 40-52: Recommend including information on what percentage of studies included in Salpeter's review had stated contraindications to metformin use. | Because of limitations in the reporting of trial eligibility criteria, the Salpeter review concluded “There was insufficient information to estimate the number of participants studied with hypoxemic co-conditions such as renal insufficiency, cardiovascular diseases, liver diseases, or pulmonary disease.” A statement to this effect has been added to the results section of KQ 1.
4 | CV mortality and all-cause mortality: A recent meta-analysis examined comparative effectiveness of glucose-lowering agents with respect to CV mortality, as well as several other outcomes: all-cause mortality, serious adverse events, myocardial infarction, stroke, HbA1c level, treatment failure (rescue treatment or lack of efficacy), hypoglycemia, and weight (Palmer et al. Comparison of Clinical Outcomes and Adverse Events Associated With Glucose-Lowering Drugs in Patients With Type 2 Diabetes JAMA July 19, 2016). In that meta-analysis, there were no significant differences in associations between any drug class as monotherapy, dual therapy, or triple therapy with odds of cardiovascular or all-cause mortality (including metformin). The meta-analysis came out after the authors submitted their review, but I recommend that they include this in their discussion and specifically address why their findings were different from the findings of the meta-analysis with respect to CV and all-cause mortality outcomes. | Thank you for identifying this recent review by Palmer et al. We have added a discussion of the review's findings and how they relate to our results.
4 | Page 32, lines 45-50: Lack of evidence with respect to harm does not necessarily mean that the harm does not exist. Overall, the studies included in the systematic review had moderate risk of bias, with no existing randomized clinical trials designed to assess the safety of the use of metformin in patients with CKD with respect to lactic acidosis. Therefore, I recommend that some of the conclusions are restated to reflect ongoing uncertainty. | We incorporated findings from the Palmer review (as noted previously) and describe the uncertainty this introduces and the need for large pragmatic comparative effectiveness trials. We also describe how the change in FDA guidance is likely to make future observational studies more useful.
4 | Tables 9 and 10 are very clear and nicely represent the SOE summary. Strengths and limitations section is well balanced. Discussion of the recent FDA recommendations for new labeling changes for metformin is important and well executed. | Thank you.