# APPENDIX D QUALITY ASSESSMENT FOR OBSERVATIONAL STUDIES

QUALITY CRITERIA

QUALITY ASSESSMENT RESPONSES—OBSERVATIONAL STUDIES

For full study citations, please refer to the report's main reference list.

Study | 1 | 2.1a | 2.1b | 2.2 | 2.3 | 2.4 | 3 | 4.1 | 4.2 | 4.3 | 5.1 | 5.2 | 5.3 | 6 | 7 | Overall Risk of Bias Rating
Aguilar, 2011^41^ | Ret | Yes | Yes | NA | Yes | Yes | Par | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Low
Ampuero, 2012^49^ | Ret | Par | Par | NA | Yes | Yes | Yes | Yes | Yes | Yes | NA | Yes | Par | Yes | No | Mod
Andersson, 2010^25^ | Ret | Yes | Par | NA | Yes | Yes | Yes | Unc | Unc | Unc | No | Yes | Yes | Yes | No | Mod
Bannister, 2014^58^ | Ret | Yes | Par | NA | Par | Yes | Unc | Yes | Yes | Yes | NA | Yes | Unc | Yes | No | Mod
Becquemont, 2015^39^ | Pro | Yes | NA | No | NA | NA | Yes | NA | Unc | Unc | NA | Unc | Unc | Yes | Yes | High
Bodmer, 2008^59^ | Mix | Yes | Yes | NA | Yes | Yes | Unc | Yes | Unc | NA | NA | Yes | Yes | Yes | No | Low
Ekstrom, 2012^40^ | Ret | Yes | Yes | NA | Yes | Yes | Yes | Yes | Unc | Unc | No | Yes | Yes | Yes | None | Mod
Eppenga, 2014^34^ | Ret | Par | No | NA | Yes | No | Yes | Yes | Unc | Yes | No | Yes | Yes | Yes | No | Mod
Eurich, 2005^26^ | Ret | Par | Par | NA | Yes | Yes | Yes | Yes | Unc | Unc | No | Yes | Yes | Yes | No | Mod
Evans, 2010^45^ | Ret | Yes | Yes | NA | Yes | Yes | Yes | Unc | Unc | Unc | NA | Yes | Yes | Yes | No | Mod
Huizinga, 2010^60^ | Ret | Yes | Par | NA | Par | Yes | Yes | Yes | No | Unc | Yes | Yes | Yes | Yes | Yes | Mod
Inzucchi, 2005^46^ | Ret | Yes | Yes | NA | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Low
Ito, 2011^36^ | Ret | Yes | Yes | NA | No | Yes | Unc | Unc | Unc | Unc | No | Unc | No | Yes | No | High
Leung, 2010^61^ | Pro | Par | Par | Unc | No | Unc | Unc | Unc | Unc | Unc | No | Yes | No | Yes | No | High
Masoudi, 2005^42^ | Ret | Yes | Yes | NA | Par | Yes | Yes | Yes | Yes | Yes | No | Yes | Par | Par | Yes | Mod
Morgan, 2014^43^ | Ret | Yes | Yes | NA | Yes | Yes | Yes | Yes | Unc | Yes | NA | Yes | Yes | Yes | No | Low
Nkontchou, 2011^50^ | Pro | Yes | Yes | No | No | Unc | Yes | Yes | Yes | Yes | NA | Unc | Unc | Yes | Yes | High
Richy, 2014^33^ | Ret | Yes | Yes | NA | No | NA | No | Yes | Unc | Unc | No | Yes | Yes | Yes | Yes | High
Romero, 2013^35^ | Pro | Yes | Yes | No | Yes | Yes | Yes | Yes | Unc | Unc | Yes | Yes | Yes | Yes | Yes | Low
Roumie, 2012^62^ | Ret | Yes | Yes | NA | Yes | Yes | Yes | Unc | Yes | Yes | NA | Yes | Yes | Yes | No | Low
Roussel, 2010^44^ | Pro | Yes | Par | No | Par | Yes | Par | Yes | No | Unc | NA | Yes | Yes | Yes | No | Mod
Shah, 2010^47^ | Ret | Yes | Yes | NA | Par | Yes | Par | Unc | Unc | Unc | NA | Yes | Yes | Yes | No | Mod
Sterner, 2012^37^ | Ret | Par | Par | NA | NA | NA | Yes | Unc | Unc | Unc | No | Yes | Unc | Yes | | High
Tinetti, 2015^48^ | Ret | Yes | Yes | NA | Yes | Yes | Yes | Yes | Unc | Unc | NA | Yes | Unc | Yes | No | Mod
Tzoulaki, 2009^64^ | Ret | Yes | Yes | NA | Yes | Yes | Yes | Yes | Yes | Yes | NA | Yes | Yes | Yes | No | Low
Wang, 2014^63^ | Ret | Yes | Yes | NA | Yes | Yes | Yes | Unc | Unc | Unc | NA | Yes | Yes | Yes | Yes | Mod
Weir, 2011^74^ | Ret | Yes | Par | NA | Yes | Yes | Yes | Unc | Unc | Unc | No | Yes | Yes | Yes | No | Mod
Weir, 2014^27^ | Ret | Par | Par | NA | Yes | Yes | Yes | Unc | Unc | Unc | Yes | Yes | Yes | Yes | No | Mod
Zhang, 2008^38^ | Ret | Yes | Yes | NA | Yes | Yes | Yes | Unc | Yes | Yes | NA | Yes | Yes | Yes | No | Low

Abbreviations: Mix = Mixed; Mod = Moderate; Par = Partial; Pro = Prospective; Ret = Retrospective; Unc = Unclear