# APPENDIX C QUALITY ASSESSMENT FOR RANDOMIZED CONTROLLED TRIALS

QUALITY CRITERIA

QUALITY ASSESSMENT RESPONSE TABLE—RCTS

For full study citations, please refer to the report's main reference list.

Study^a^ | 1a | 1b | 2 | 3a | 3b | 3c | 3d | 4 | 5 | 6 | Overall Risk of Bias Rating
Blonde, 2002^51^ | Unclear | Unclear | Low | Low | Low | NA | NA | Unclear | Low | Unclear | Unclear
Cryer, 2005^52^ | Unclear | Unclear | High | NA^b^ | Low | Unclear | NA | Low | Low | Low | Low
Garber, 2002^53^ | Unclear | Unclear | Low | Low | Low | NA | NA | Unclear | Low | Unclear | Unclear
Gregorio, 1999^54^ | Low | Unclear | Unclear | Unclear | NR | Low | NR | Low | Low | Low | High
Hanefeld, 2004^55^ | Low | Unclear | Unclear | Low | NA | Unclear | Low | Low | NA | Low | Low
Marre, 2002^56^ | Unclear | Unclear | Low | Low | Low | NA | NA | Unclear | Low | Unclear | Unclear
Schweizer, 2009^57^ | Unclear | Unclear | Low | Low | Low | Low | NA | Low | Low | Low | Low

a The companion paper does not appear in this table.

b For mortality, blinding does not apply.