# APPENDIX B SEARCH STRATEGY

Key Question 1—PubMed: November 20, 2015

Set | Query | Results
1 | “Acidosis, Lactic”[Mesh] OR “Lactic Acid/blood”[Mesh] OR “lactic acidosis”[tiab] OR hyperlactatemia[tiab] OR hyperlactataemia[tiab] | 13168
2 | “Diabetes Mellitus”[Mesh] OR diabetes[tiab] OR diabetic[tiab] | 513282
3 | “Renal Insufficiency, Chronic”[Mesh] OR “Heart Failure”[Mesh] OR “Hepatic Insufficiency”[Mesh] OR “Liver Cirrhosis”[Mesh] OR “Diabetic Nephropathies”[Mesh] OR “Aged”[Mesh] OR “Age Factors”[Mesh] OR “Geriatrics”[Mesh] OR CKD[tiab] OR CRD[tiab] OR “chronic kidney”[tiab] OR “chronic renal”[tiab] OR “heart failure”[tiab] OR CHF[tiab] OR “chronic liver disease”[tiab] OR “liver insufficiency”[tiab] OR “hepatic insufficiency”[tiab] OR “liver cirrhosis”[tiab] OR “diabetic nephropathies”[tiab] OR “diabetic nephropathy”[tiab] OR aged[tiab] OR elderly[tiab] OR older[tiab] OR geriatric[tiab] | 3427067
4 | “Metformin”[Mesh] OR metformin[tiab] | 13077
5 | (randomized controlled trial[pt] OR controlled clinical trial[pt] OR randomized[tiab] OR randomised[tiab] OR randomization[tiab] OR randomisation[tiab] OR placebo[tiab] OR randomly[tiab] OR trial[tiab] OR groups[tiab] OR Clinical trial[pt] OR “clinical trial”[tiab] OR “clinical trials”[tiab] OR “evaluation studies”[Publication Type] OR “evaluation studies as topic”[MeSH Terms] OR “evaluation study”[tiab] OR evaluation studies[tiab] OR “intervention studies”[MeSH Terms] OR “intervention study”[tiab] OR “intervention studies”[tiab] OR “comparative study”[Publication Type] OR “comparative study”[tiab] OR “case-control studies”[MeSH] OR “cohort studies”[MeSH] OR “Drug Information Services”[Mesh] OR “case-control”[tiab] OR cohort[tiab] OR “longitudinal”[tiab] OR longitudinally[tiab] OR prospective[tiab] OR prospectively[tiab] OR “retrospective”[tiab] OR “follow up”[tiab] OR “Case Reports” [Publication Type] OR “case series”[tiab] OR pharmacovigilance[tiab]) NOT (Editorial[ptyp] OR Letter[ptyp] OR Comment[ptyp]) NOT (animals[mh] NOT humans[mh]) | 6464701
6 | #1 AND (#2 OR #3) AND #4 AND #5 | 298

Key Question 2—PubMed: November 20, 2015

Set | Query | Results
1 | “Diabetes Mellitus”[Mesh] OR diabetes[tiab] OR diabetic[tiab] | 513282
2 | “Renal Insufficiency, Chronic”[Mesh] OR “Heart Failure”[Mesh] OR “Hepatic Insufficiency”[Mesh] OR “Liver Cirrhosis”[Mesh] OR “Diabetic Nephropathies”[Mesh] OR “Aged”[Mesh] OR “Age Factors”[Mesh] OR “Geriatrics”[Mesh] OR CKD[tiab] OR CRD[tiab] OR “chronic kidney”[tiab] OR “chronic renal”[tiab] OR “heart failure”[tiab] OR CHF[tiab] OR “chronic liver disease”[tiab] OR “liver insufficiency”[tiab] OR “hepatic insufficiency”[tiab] OR “liver cirrhosis”[tiab] OR “diabetic nephropathies”[tiab] OR “diabetic nephropathy”[tiab] OR aged[tiab] OR elderly[tiab] OR older[tiab] OR geriatric[tiab] OR “Acidosis, Lactic”[Mesh] OR “Lactic Acid/blood”[Mesh] OR “lactic acidosis”[tiab] OR hyperlactatemia[tiab] OR hyperlactataemia[tiab] OR “Metformin/adverse effects”[Mesh] | 3438398
3 | “Metformin”[Mesh] OR metformin[tiab] | 13077
4 | (randomized controlled trial[pt] OR controlled clinical trial[pt] OR randomized[tiab] OR randomised[tiab] OR randomization[tiab] OR randomisation[tiab] OR placebo[tiab] OR randomly[tiab] OR trial[tiab] OR groups[tiab] OR Clinical trial[pt] OR “clinical trial”[tiab] OR “clinical trials”[tiab] OR “evaluation studies”[Publication Type] OR “evaluation studies as topic”[MeSH Terms] OR “evaluation study”[tiab] OR evaluation studies[tiab] OR “intervention studies”[MeSH Terms] OR “intervention study”[tiab] OR “intervention studies”[tiab] OR “comparative study”[Publication Type] OR “comparative study”[tiab] OR “cohort studies”[MeSH] OR cohort[tiab] OR “longitudinal”[tiab] OR longitudinally[tiab] OR prospective[tiab] OR prospectively[tiab] OR “retrospective”[tiab] OR “follow up”[tiab]) NOT (Editorial[ptyp] OR Letter[ptyp] OR Comment[ptyp] OR “Case Reports” [Publication Type]) NOT (animals[mh] NOT humans[mh]) | 4823517
5 | #1 AND #2 AND #3 AND #4 | 2218

Key Question 1—Embase: November 20, 2015

Set | Query | Results
1 | ‘lactic acidosis’/exp OR ‘lactic acid’/exp OR “lactic acidosis”:ab,ti OR hyperlactatemia:ab,ti OR hyperlactataemia:ab,ti | 67408
2 | ‘diabetes mellitus’/exp OR diabetes:ab,ti OR diabetic:ab,ti | 825055
3 | ‘chronic kidney failure’/exp OR ‘heart failure’/exp OR ‘liver failure’/exp OR ‘liver cirrhosis’/exp OR ‘diabetic nephropathy’/exp OR ‘aged’/exp OR ‘age’/exp OR ‘geriatrics’/exp OR CKD:ab,ti OR CRD:ab,ti OR “chronic kidney”:ab,ti OR “chronic renal”:ab,ti OR “heart failure”:ab,ti OR CHF:ab,ti OR “chronic liver disease”:ab,ti OR “liver insufficiency”:ab,ti OR “hepatic insufficiency”:ab,ti OR “liver cirrhosis”:ab,ti OR “diabetic nephropathies”:ab,ti OR “diabetic nephropathy”:ab,ti OR aged:ab,ti OR elderly:ab,ti OR older:ab,ti OR geriatric:ab,ti | 4045218
4 | ‘metformin’/exp OR metformin:ab,ti | 41795
5 | (‘randomized controlled trial’/exp OR ‘crossover procedure’/exp OR ‘double blind procedure’/exp OR ‘single blind procedure’/exp OR random*:ab,ti OR factorial*:ab,ti OR crossover*:ab,ti OR (cross NEAR/1 over*):ab,ti OR placebo*:ab,ti OR (doubl* NEAR/1 blind*):ab,ti OR (singl* NEAR/1 blind*):ab,ti OR assign*:ab,ti OR allocat*:ab,ti OR volunteer*:ab,ti OR ‘clinical study’/exp OR ‘clinical trial’:ti,ab OR ‘clinical trials’:ti,ab OR ‘controlled study’/exp OR ‘evaluation’/exp OR ‘evaluation study’:ab,ti OR ‘evaluation studies’:ab,ti OR ‘intervention study’:ab,ti OR ‘intervention studies’:ab,ti OR ‘case control’:ab,ti OR ‘cohort analysis’/exp OR cohort:ab,ti OR longitudinal*:ab,ti OR prospective:ab,ti OR prospectively:ab,ti OR retrospective:ab,ti OR ‘follow up’/exp OR ‘follow up’:ab,ti OR ‘comparative effectiveness’/exp OR ‘comparative study’/exp OR ‘comparative study’:ab,ti OR ‘comparative studies’:ab,ti OR ‘drug surveillance program’/exp OR pharmacovigilance:ab,ti OR ‘case report’/exp OR ‘case study’/exp OR ‘case series”:ab,ti) NOT (‘editorial’/exp OR ‘letter’/exp OR ‘note’/exp) | 11802586
6 | #1 AND (#2 OR #3) AND #4 AND #5 | 1205
7 | #6 AND [embase]/lim NOT [medline]/lim | 387

Key Question 2—Embase: November 20, 2015

Set | Query | Results
1 | ‘diabetes mellitus’/exp OR diabetes:ab,ti OR diabetic:ab,ti | 825055
2 | ‘chronic kidney failure’/exp OR ‘heart failure’/exp OR ‘liver failure’/exp OR ‘liver cirrhosis’/exp OR ‘diabetic nephropathy’/exp OR ‘aged’/exp OR ‘age’/exp OR ‘geriatrics’/exp OR CKD:ab,ti OR CRD:ab,ti OR “chronic kidney”:ab,ti OR “chronic renal”:ab,ti OR “heart failure”:ab,ti OR CHF:ab,ti OR “chronic liver disease”:ab,ti OR “liver insufficiency”:ab,ti OR “hepatic insufficiency”:ab,ti OR “liver cirrhosis”:ab,ti OR “diabetic nephropathies”:ab,ti OR “diabetic nephropathy”:ab,ti OR aged:ab,ti OR elderly:ab,ti OR older:ab,ti OR geriatric:ab,ti OR ‘lactic acidosis’/exp OR ‘lactic acid’/exp OR “lactic acidosis”:ab,ti OR hyperlactatemia:ab,ti OR hyperlactataemia:ab,ti OR ‘metformin’/exp/dd_ae | 4104859
3 | ‘metformin’/exp OR metformin:ab,ti | 41795
4 | (‘randomized controlled trial’/exp OR ‘crossover procedure’/exp OR ‘double blind procedure’/exp OR ‘single blind procedure’/exp OR random*:ab,ti OR factorial*:ab,ti OR crossover*:ab,ti OR (cross NEAR/1 over*):ab,ti OR placebo*:ab,ti OR (doubl* NEAR/1 blind*):ab,ti OR (singl* NEAR/1 blind*):ab,ti OR assign*:ab,ti OR allocat*:ab,ti OR volunteer*:ab,ti OR ‘clinical study’/exp OR ‘clinical trial’:ti,ab OR ‘clinical trials’:ti,ab OR ‘controlled study’/exp OR ‘evaluation’/exp OR ‘evaluation study’:ab,ti OR ‘evaluation studies’:ab,ti OR ‘intervention study’:ab,ti OR ‘intervention studies’:ab,ti OR ‘cohort analysis’/exp OR cohort:ab,ti OR longitudinal*:ab,ti OR prospective:ab,ti OR prospectively:ab,ti OR retrospective:ab,ti OR ‘follow up’/exp OR ‘follow up’:ab,ti OR ‘comparative effectiveness’/exp OR ‘comparative study’/exp OR ‘comparative study’:ab,ti OR ‘comparative studies’:ab,ti) NOT (‘case report’/exp OR ‘case study’/exp OR ‘case series”:ab,ti OR ‘editorial’/exp OR ‘letter’/exp OR ‘note’/exp) | 9867450
5 | #1 AND #2 AND #3 AND #4 | 8122
6 | #5 AND [embase]/lim NOT [medline]/lim | 2610

Key Question 2—Cochrane Central Register of Controlled Trials: November 20, 2015

Set | Terms | Results
1 | [mh “Diabetes Mellitus”] | 17098
2 | diabetes:ab,ti OR diabetic:ab,ti | 36056
3 | #1 OR #2 | 37538
4 | [mh “chronic Renal Insufficiency”] OR [mh “Heart Failure”] OR [mh “Hepatic Insufficiency”] OR [mh “Liver Cirrhosis”] OR [mh “Diabetic Nephropathies”] OR [mh Aged] OR [mh “Age Factors”] OR [mh Geriatrics] OR [mh “lactic Acidosis”] OR [mh “Lactic Acid”] OR [mh Metformin/AE] | 24846
5 | “lactic acidosis”:ab,ti OR hyperlactatemia:ab,ti OR hyperlactataemia:ab,ti OR CKD:ab,ti OR CRD:ab,ti OR “chronic kidney”:ab,ti OR “chronic renal”:ab,ti OR “heart failure”:ab,ti OR CHF:ab,ti OR “chronic liver disease”:ab,ti OR “liver insufficiency”:ab,ti OR “hepatic insufficiency”:ab,ti OR “liver cirrhosis”:ab,ti OR “diabetic nephropathies”:ab,ti OR “diabetic nephropathy”:ab,ti OR aged:ab,ti OR elderly:ab,ti OR older:ab,ti OR geriatric:ab,ti | 85344
6 | #4 OR #5 | 98264
7 | [mh Metformin] | 1651
8 | Metformin:ab,ti | 3292
9 | #7 OR #8 | 3417
10 | #9 AND #6 AND #3 | 471
11 | Limit: Cochrane Central Register of Controlled Trials | 454