# SUMMARY AND DISCUSSION

We evaluated a broad range of nonpharmacologic interventions for perimenopausal and postmenopausal women with VMS, evaluating effects on VMS, health-related quality of life, and adverse events. Our review identified good- and fair-quality SRs for all of the eligible intervention categories. In addition, we identified 14 new RCTs, representing a 42% increase in RCTs in the past 4 years. Based on the number of trials, the evidence base is most developed for acupuncture, followed by relaxation, then exercise and yoga. Except for acupuncture, most trials used waitlist controls as the comparator and reported outcomes at 6 months or earlier. There were few comparative effectiveness trials. However, the growing evidence base allowed for updated meta-analyses and estimates of effect for most interventions compared with inactive or attention controls. Almost all studies reported effects on VMS frequency or severity; fewer reported effects on quality of life, insomnia, or psychological symptoms. Adverse effects were rare but often not reported systematically.

## LIMITATIONS

### Limitations of the Umbrella Review

The novel approach of supplementing a review of reviews with findings from recently published RCTs allowed for assessment of a broad range of interventions. This approach made it possible for us to synthesize both quantitatively and qualitatively the most current information for each of the 4 categories of nonpharmacologic interventions for VMS. A significant limitation to this approach is that we relied on the authors' judgments about risk of bias for individual trials and the appropriateness of their search strategies, eligibility criteria, and synthesis of the evidence. We confirmed (and at times corrected) data included in meta-analysis that we updated, but we did not confirm all of the study characteristics and outcomes data reported in the SRs. We limited our review to English-language publications, which may have excluded potentially informative evidence.

### Limitations of the Studies

Most of the RCTs discussed in our report were relatively small, short-term trials. Adverse events were often not reported. All of the studies used self-report assessments, and most did not mask participants to intervention allocation, thereby introducing the risk that patients allocated to the active interventions might exaggerate clinical improvement. Few of the trials compared 2 or more active interventions, which could have informed clinical decision-making for patients or healthcare providers faced with deciding among various therapeutic options. Several of the trials used usual care or waitlist controls, which do not control for nonspecific effects of a given intervention, and as such do not provide insights about an intervention's potential mechanisms of action. However, usual care controls serve as an appropriate control for trials that aim to inform patients or healthcare providers what to expect from a given course of treatment relative to not undergoing that course of treatment.^105^ Trials that include a usual care arm introduce a risk of performance bias, which may either overestimate or underestimate the true effect size of an intervention.^106^

Approximately half of the acupuncture trials used sham acupuncture controls. The purpose of a sham procedure or attention control is to evaluate whether a given intervention's mechanisms of action involve physiological processes that are independent of nonspecific effects that can be attributed to health care providers' care and attention or individual patients' beliefs and expectations. In the case of acupuncture, there is considerable debate about the appropriate control.^107,108^ Some argue that sham procedures may not be physiologically inert, and that a usual care arm may be a more appropriate comparison for trials that aim to inform clinical practice, as opposed to determining the specific effects of an intervention.

Clinical interpretation of the findings from this report was also hampered by the use of many different outcome measures across trials, thereby requiring us to report standardized mean differences, which are difficult to interpret clinically. A more readily interpretable outcome would be the proportion of women achieving the minimum clinically important response, but this value has not been established for any of the primary outcomes used in these studies. This was especially true for quality-of-life measures, with the additional caveat that there is no universally accepted quality-of-life assessment instrument specific to menopausal symptoms. Authors of the SRs frequently considered symptom inventories or functional status questionnaires as health-related or menopausal-specific quality-of-life instruments. We used the same terms reported by the authors of the SRs, with the understanding that the underlying constructs measured are not likely to be truly health-related or menopausal-specific quality of life.

Unexplained heterogeneity evident in some of our meta-analyses represents another limitation of the existing evidence. The source of this heterogeneity across studies is probably multifactorial, with poor study quality, variable patient eligibility criteria, the use of a wide variety of different outcome instruments, differing doses and duration of treatments, and other factors all likely contributing to statistical heterogeneity.

## SUMMARY OF EVIDENCE

### Strength of Evidence (SOE)

We found evidence that acupuncture (moderate SOE) and yoga (low SOE) improve VMS more than controls. A trial that compared acupuncture to enhanced self-care in women with hot flashes and breast cancer was published after our search date, and also found benefit for hot flashes.^109^ However, traditional acupuncture was no better than sham acupuncture. Hypnosis was effective in women with breast cancer (low SOE). Neither structured exercise (moderate SOE) nor paced respiration (low SOE) improved VMS. Evidence was insufficient for applied relaxation and mindfulness-based stress reduction. No trials evaluated qigong, tai chi, or meditation.

Effects of interventions on health-related quality of life were reported less frequently, more inconsistently, and using measures that did not always conform to standard definitions for this construct. Consistent with effects on VMS, acupuncture improved health-related quality of life when compared with a waitlist control (moderate SOE) but not when compared with sham acupuncture (moderate SOE). Yoga did not improve health-related quality of life (insufficient SOE). The SOE for adverse effects was rated insufficient because of inconsistent reporting.

In Table 12, we summarize the SOE for effects of interventions compared with control on VMS—the priority symptom for many perimenopausal and postmenopausal women.^110^ Few trials compared these interventions with active interventions such as hormone therapy or gabapentin, and none of the interventions were compared with antidepressants. Because of the sparseness of evidence for these comparisons, we did not rate the SOE.

Table 12 Strength of Evidence for Effects of Interventions on VMS

Comparison | # RCTs (Patients) | Findings | Strength of Evidence (Rationale by Domain)
Acupuncture vs waitlist | 4 (501) | SMD 0.66 lower (1.06 lower to 0.26 lower) | Moderate Low ROB, consistent, direct, imprecise
Acupuncture vs sham acupuncture | 8 (644) | SMD 0.35 lower (0.70 lower to 0.01 higher) | Moderate Low ROB, consistent, direct, imprecise
Yoga vs control | 4 (157) | SMD 0.36 lower (0.65 lower to 0.07 lower) | Low Moderate ROB, consistent, direct, imprecise
Structured exercise vs control | 4 (431) | SMD 0.08 lower (0.33 lower to 0.16 higher) | Moderate Moderate ROB, consistent, direct, precise
Paced respiration vs control | 3 (161) | SMD 0.04 higher (0.73 lower to 0.82 higher) | Low Low ROB, inconsistent, direct, imprecise
Applied relaxation vs control | 2 (82) | 1 RCT showed small benefit and 1 RCT showed no effect | Insufficient Moderate ROB, inconsistent, direct, imprecise
Hypnosis vs control | 3 (274) | No pooled estimate. Effect size ranged from 0.479 to 1.25 | Low Moderate ROB, consistent, direct, imprecise
Mindfulness-based stress reduction vs control | 1 (110) | No reduction in hot flashes | Not rated

Abbreviations: RCT = randomized controlled trial; ROB = risk of bias; SMD = standardized mean difference

## CLINICAL IMPLICATIONS

The VA does not have a current guideline that addresses the management of menopause in general, and few clinical practice guidelines specifically address nonpharmacologic treatment strategies for VMS. One exception is a 2015 position statement from the North American Menopause Society.^25^ This statement recommends cognitive behavioral therapy, hypnosis, and, with caution, mindfulness-based stress reduction. Exercise, yoga, paced respiration, relaxation, and acupuncture were considered but not recommended. Our updated analysis shows benefit for yoga, acupuncture, and hypnosis compared (primarily) with no treatment and only very limited evidence for mindfulness-based stress reduction. These updated results should be considered when making clinical or policy recommendations.

## RESEARCH GAPS/FUTURE RESEARCH

For some interventions such as acupuncture and yoga, there is evidence of benefit. However, SOE is low to moderate, so larger, high-quality trials are needed. Comparative effectiveness trials would be more likely to inform policy and clinical decision-making than sham- or placebo-controlled effectiveness trials. This may be especially true in the search for alternatives to pharmacologic approaches to managing menopausal symptoms, where clinical effectiveness outcomes may need to be counterbalanced by other outcomes of importance to women, healthcare providers, and policymakers, such as potential harm, cost, overall utility, and women's preferences. Research is needed, as well, to better understand considerations related to treatment options that women with menopausal symptoms consider to be most important.

The design of some of the RCTs included in our review can inform future research. For example, the internet-based, applied relaxation trial by Lindh-Astrand et al^61^ is innovative in that it explored a way to make treatment more readily accessible and affordable. However, this trial had an exceptionally high drop-out rate. More research is needed to better understand how to engage and retain patients in internet-based interventions. Pragmatic trials such as the one recently published by Avis et al^52^ simulated clinical practice by allowing patients and acupuncturists to negotiate the number and frequency of acupuncture treatments and allowing the acupuncturists to design and administer treatments as they would outside the context of the clinical trial. Nonpharmacologic clinical interventions such as acupuncture, yoga, meditation, and exercise lend themselves well to these types of pragmatic trials, with the caveat that pragmatic, comparative effectiveness trials are not designed to determine mechanisms of actions or to estimate the extent to which observed clinical benefit associated with a given intervention may be attributable to specific versus nonspecific effects.

None of the RCTs included in this umbrella review specifically involved Veterans. Additional research is needed to evaluate the acceptability, feasibility, and comparative effectiveness of nonpharmacologic approaches to managing menopausal symptoms for women Veterans in VA primary care clinics, as well as other settings and patient populations such as medically underserved populations.

## CONCLUSIONS

Compared with waitlist controls, evidence from RCTs support acupuncture and yoga for reducing VMS and the impact of such symptoms on women's activities and health-related quality life. The strength of evidence, however, is low to moderate. Moderately good evidence shows no benefit from structured exercise for VMS, but engaging in exercise is known to be important for other reasons. The evidence in support of the effectiveness of mindfulness or relaxation is mixed, with some promising evidence that needs replication for hypnosis. There is insufficient evidence to draw conclusions about the effectiveness of these nonpharmacologic therapies for improving sleep, depression, or anxiety. The safety of the nonpharmacologic, nonhormonal approaches evaluated in this report has not been rigorously examined, but there is no clear signal for a significant potential for harm. Overall, most of the data included in this report comes from smaller studies with homogenous participant populations. Larger trials of populations more reflective of the diversity of women experiencing VMS will be necessary to discern the effectiveness of nonpharmacologic interventions in symptomatic menopausal women.