# RESULTS

## LITERATURE FLOW

Figure 1 shows the flow of articles through the literature search and screening process. The literature search for SRs identified 239 unique citations from a combined search of PubMed and the Cochrane Database of Systematic Reviews. After applying inclusion and exclusion criteria at the title-and-abstract screening level, 37 full texts were retrieved for further review. Of these, 10 were retained for data abstraction.

Figure 1 Literature Flow Chart

A separate literature search for RCTs published after January 2012 identified 1135 unique citations from a combined search of PubMed, EMBASE, CINAHL, and the Allied and Complementary Medicine Database. One additional citation was identified by review of study bibliographies or contact with authors. After applying inclusion and exclusion criteria at the title-and-abstract screening level, 68 full texts were retrieved for further review. After eliminating studies included in eligible reviews and applying eligibility criteria at the full-text review level, 14 were retained for data abstraction, and 2 were identified as companion papers (ie, secondary analyses to studies included in an eligible review).

## CHARACTERISTICS OF INCLUDED STUDIES

### Systematic Reviews

We identified 10 eligible SRs (5 good quality and 5 fair quality): 3 addressed acupuncture;^40-42^ 1 addressed yoga;^43^ 1 addressed structured exercise;^44^ and 5 addressed meditation, mindfulness-based practices, hypnosis, relaxation, or mixed interventions.^45-49^ All SRs evaluated interventions in women who were perimenopausal or postmenopausal and 5 required women to report bothersome frequency of VMS. Four restricted their focus to women with a history of breast cancer. Seven SRs included only RCTs. Four reported summary estimates of treatment effect from meta-analyses, while 6 synthesized results qualitatively.

### New Randomized Controlled Trials

We identified 14 eligible RCTs published after the SRs (hereafter described as “new RCTs”) that evaluated a range of interventions: 4 addressed acupuncture;^50-53^ 2 addressed yoga;^54,55^ 6 addressed relaxation, paced respiration, or hypnosis;^56-61^ and 2 addressed structured exercise.^62,63^ All new RCTs enrolled perimenopausal or postmenopausal women with VMS. Three RCTs focused on breast cancer survivors. Trials randomized 40 to 327 (median = 63 patients and reported outcomes at 5 to 24 (median = 11) weeks. All RCTs reported the effects of interventions on VMS; however, quality of life and other outcomes were reported less frequently.

For each of the 4 intervention categories, we focus our discussion on the SR(s) having the highest quality and most relevance to the primary outcomes of interest: VMS symptoms and health-related quality of life. Results from other SRs are described when they provided unique information. We then discuss results from the new RCTs and our updated syntheses (quantitative or qualitative) that included these additional studies. Results are further organized by inactive and active comparators. Last, we describe the findings for the secondary outcomes across all 4 intervention categories, which include adverse effects as well as effects on sleep, depression, and anxiety.

## KQ: In women with vasomotor symptoms (VMS) that are associated with perimenopause or postmenopause, what are the effects on VMS, health-related quality of life, and adverse events of the following nonpharmacologic, nonhormonal interventions?

- Acupuncture
- Yoga, tai chi, and qigong
- Structured exercise
- Meditation, mindfulness, hypnosis, and relaxation

### ACUPUNCTURE

#### Key Points

- We identified one good-quality SR published in 2013 and 2 fair-quality SRs published in 2013 and 2015 that met eligibility criteria. The good-quality review included women with menopausal VMS from any cause, and the 2 fair-quality reviews included only women with any type of cancer. All 3 SRs included RCTs that compared acupuncture with no acupuncture, sham acupuncture, hormone therapy, or relaxation.
- The Dodin et al meta-analysis suggests that acupuncture is effective at reducing VMS frequency (SMD -0.66, 95% CI -1.06 to -0.26, I^2^ = 61.7%, 5 trials) and VMS severity (SMD -0.49, 95% CI -0.85 to -0.13, I^2^ = 18.1%, 4 trials) and improving quality of life (SMD -0.93, 95% CI -1.20 to -0.67, I^2^ = 0.0%, 3 trials) when compared with no acupuncture. This translates to an average of 3 fewer hot flashes daily.
- Updated meta-analysis suggests that acupuncture is not effective at reducing VMS frequency (SMD -0.21, 95% CI -0.49 to 0.07, I^2^ = 53.5%, 10 trials) compared with sham acupuncture, but there is a modest, positive effect associated with acupuncture for reducing VMS severity compared with sham acupuncture (SMD -0.35, 95% CI -0.70 to 0.01, I^2^ = 66.5%, 8 trials). Acupuncture does not appear to be more effective than sham acupuncture in improving quality of life as assessed by symptom inventories (SMD -0.23, 95% CI -1.40 to 0.95, I^2^ = 77.0%, 5 trials).
- Meta-analysis suggests that acupuncture is associated with much higher daily VMS frequency compared with hormone therapy (SMD 3.18, 95% CI 2.06 to 4.29, I^2^ = 0%, 3 trials). This translates to 13 more hot flashes daily. Acupuncture and hormone therapy, however, did not differ in effects on VMS severity (SMD 0.53, 95% CI -0.14 to 1.20, 2 trials), but trials were small and 95% CI wide.
- We identified 4 relevant, low risk of bias RCTs published since 2012 that were not included in the eligible SRs. Two RCTs compared 8- or 12-week courses of acupuncture with sham acupuncture among 327 and 20 women with VMS; one compared 6 months of acupuncture with a waitlist control among 209 women with VMS; and one 4-arm trial randomized 120 breast cancer survivors to 8 weeks of electroacupuncture versus gabapentin versus sham acupuncture versus placebo gabapentin.

#### Systematic Reviews

##### Study characteristics

We identified 3 eligible SRs evaluating the effectiveness of acupuncture for VMS and quality of life. One was a good-quality Cochrane Collaboration SR by Dodin et al^40^ published in 2013, and 2 were fair-quality SRs that were qualitative summaries of RCTs published in 2013^64^ and 2015^41^ evaluating acupuncture among women with cancer (primarily breast cancer) who reported VMS. The Dodin et al SR included all but 3 of the individual RCTs that were also included in the 2 fair-quality SRs. Dodin et al excluded one RCT because of insufficient information provided about VMS experienced by the participants,^65^ and 2 RCTs were indexed in the literature databases after the search date of January 15, 2013.^66,67^

For the purposes of this report, we focus on the SR by Dodin et al^40^ because it did not limit inclusion to trials of women with a history of cancer, it included all but 3 RCTs also included in the other 2 SRs, it conducted meta-analyses pertinent to this report, and it was judged to be of higher quality than the other 2 SRs. Additionally, the other SRs did not provide a quantitative synthesis of findings.

Dodin et al included 16 RCTs^68-83^ comparing any type of acupuncture with no acupuncture, sham acupuncture, or other treatments for reducing menopausal hot flashes and improving the quality of life of symptomatic perimenopausal and postmenopausal women. Of the 16 RCTs, one is not pertinent to our report because the study intervention was moxibustion alone,^70^ which is not technically acupuncture. Collectively, the 15 relevant RCTs included 1127 women. The minimum number of daily VMS for inclusion in the trials was 2 to 7 in the 8 RCTs that reported this inclusion criterion. All RCTs included perimenopausal or postmenopausal women. Five exclusively enrolled women who had recently completed treatment for breast cancer, and one included only women who had undergone bilateral oophorectomy.

Duration of acupuncture treatments ranged from 4 to 12 weeks across the RCTs. Traditional acupuncture was administered in 11 trials, electroacupuncture in 3, and a combination of acupuncture and acupressure in one RCT. Standardized or semistandardized acupuncture treatment protocols were employed in 12 RCTs, with the number of acupuncture points needled at each treatment session ranging from 4 to 13. Individualized treatments were administered in the other 3 RCTs. Although 6 of the 15 applicable trials reported durability of effect at 3 to 12 months, the SR by Dodin et al^40^ did not address durability of treatment effect.

Twelve RCTs reported daily VMS as assessed by a self-report symptom diary. The remaining 3 also assessed daily VMS frequency but reported the findings as a Hot Flash Score, calculated by multiplying the number of VMS per day by self-reported VMS severity. Three RCTs assessed health-related quality of life using the Menopause-specific Quality of Life (MENQOL) instrument, SF-36, or a visual analog scale. Sleep quality or quantity was assessed in 4 RCTs using the Women's Health Initiative Insomnia Rating Scale, Pittsburgh Sleep Quality Index, or number of hours of sleep per night. The Kupperman Index was used in 3 RCTs to assess menopause-related symptoms. Two RCTs assessed symptoms of depression using the Beck Depression Inventory, 2 assessed symptoms of anxiety, one used the Greene Climacteric Scale, and one used the Women's Health Questionnaire. Authors of the SR considered the MENQOL, the Kupperman Index, the Greene Climacteric Scale, and the Women's Health Questionnaire as measures of quality of life.

Characteristics of the SR and included RCTs are summarized in Table 3.

Table 3 Study Characteristics: Dodin et al 2013^40^

Characteristic | Value
Systematic review
Number of included trials | 15^a^
Number of patients | 1127
Date of SR literature search | January 2013
Age range, years | 40-76
RCTs included in the SR
Study years | 2006-2013
Countries
USA | 6
Sweden | 3
South Korea | 2
Norway | 2
China | 1
Denmark | 1
Population
Perimenopausal or postmenopausal | 13
Women who had completed treatment for breast cancer | 1
Women who had ovaries surgically removed | 1
Acupuncture interventions
Traditional acupuncture | 11
Electroacupuncture | 3
Acupuncture plus acupressure | 1
Planned number of acupuncture treatments | 5-36
Length of intervention period | 4-12 weeks
Training of persons administering acupuncture
Licensed acupuncturist | 7
Physiotherapist | 4
Traditional Korean medical doctor | 2
Not reported | 2
Comparisons^b^
No acupuncture or usual care only | 5
Sham acupuncture | 10
Hormone therapy | 3
Relaxation | 1
Outcomes
Daily VMS diary | 15
VMS frequency | 12
VMS severity | 5
Hot flash score (frequency times severity) | 3
Kupperman Index | 3
MENQOL | 2
Sleep quality (various measures) | 4
Timing of last outcome assessment after randomization
3 days after each treatment | 1
8-24 weeks | 10
6-24 months | 4

a We excluded one of the 16 RCTs because the study intervention was moxibustion, which is not technically acupuncture.

b Some RCTs included 3 arms and thus had 2 comparators.

##### Risk of bias—Systematic review

In the SR, authors assessed each included RCT using the Cochrane Risk of Bias Tool across 6 domains (2 selection bias domains, detection bias, attrition bias, reporting bias, and other). Of the 12 trials that contributed data to meta-analyses reported in the SR, 10 were judged by the authors to have 4 or more low risk of bias domains (out of 6) and 2 were judged to have 3 low risk of bias domains. Applying the Cochrane guidance for assessing overall risk of bias, 2 RCTs would be rated as low risk and 10 would be rated as high risk.

#### New Randomized Controlled Trials

##### Study characteristics

We identified 4 relevant RCTs published after 2012 that assessed the impact of acupuncture on VMS or quality of life among perimenopausal or postmenopausal women.^50-53^ Avis et al^52^ compared acupuncture with no acupuncture for the treatment of VMS. In this RCT, 209 perimenopausal or postmenopausal women who reported an average of 4 or more VMS per day were randomized to receive up to 20 acupuncture treatments within 6 weeks or to a waitlist control. In a 4-arm trial, Mao et al^51^ compared acupuncture with sham acupuncture and randomized 120 breast cancer survivors experiencing bothersome hot flashes to gabapentin versus placebo versus 10 treatments (8 weeks) of electroacupuncture, compared with sham acupuncture. Ee et al^50^ randomized 327 perimenopausal and postmenopausal women experiencing bothersome hot flashes to 10 treatments (8 weeks) of acupuncture or sham acupuncture. Nedeljkovic et al randomized 40 postmenopausal women with at least 20 hot flashes per week to 12-weeks of acupuncture, sham acupuncture, Chinese herbal medicine, or placebo.

##### Outcome measures

In Avis et al^52^ primary outcomes were daily hot flash frequency and severity, as measured by a daily hot flash diary. Secondary outcomes were hot flash interference with daily life, sleep quality, depressive symptoms, somatic and other symptoms, anxiety, and quality of life assessed at end of treatment and 6 months post-treatment. In Mao et al^51^ the primary outcome was the once per week average hot flash composite score as measured by a daily hot flash diary. Participants documented their hot flash frequency and severity each day starting from baseline until end of intervention and then for 1 week at 12 and 24 weeks (16 weeks post-treatment). In Ee et al,^50^ the primary outcome was a hot flash score reflecting frequency and severity at the end of treatment. Secondary outcomes included quality of life, anxiety, depression, and adverse events. Participants recorded the number of daily mild, moderate, severe, and very severe hot flashes for 7 days using a validated hot flash diary. Participants were assessed for secondary outcomes at 4 weeks, the end of treatment, and then 3 and 6 months after the end of treatment. Hot flash frequency and severity, measured with a daily diary at 12 and 24 weeks, were the primary outcomes in the study by Nedeljkovic et al. Menopause-related quality of life was assessed using the Menopause Rating Scale-II.

Characteristics of the 4 new RCTs are summarized in Table 4.

Table 4 Study Characteristics of New RCTs

Study Country | Population # Women randomized Type of menopause # Hot flashes Mean age in years (range) | Intervention Category/type Session frequency/duration | Comparator Category/type Session frequency/duration | General Outcomes Instruments^a^
Ee 2016^50^ Australia | 327 Perimenopausal and postmenopausal ≥7 moderate per day Intervention: 55.2 (4.3) Comparator: 54.8 (4.2) | Acupuncture 10 treatments over 8 weeks | Sham acupuncture (Park Sham device) 10 sessions over 8 weeks | 8 and 24 weeks:; - Hot flash frequency; - Hot flash severity; - Hot flash score; - Menopause QOL; - Hospital Anxiety and Depression Scale; - Adverse events
Avis 2016^52^ USA | 209 Perimenopausal and postmenopausal ≥4 per day 53.8 (3.5) | Acupuncture Up to 20 treatments over 24 weeks | Waitlist control: usual care for 6 months followed by 6-month course of acupuncture treatments | Several time points up to 26 weeks:; - Hot flash frequency; - Hot flash severity; - Hot flash Daily Interference; - Pittsburgh Sleep Quality Index and PROMIS short form Sleep Disturbance; - Women's Health Questionnaire; - Center for Epidemiologic Studies Depression Scale; - General Anxiety Disorder Scale and PROMIS short form Anxiety; - Perceived Stress Scale; - Medical Outcomes Study short form, Physical and Mental Health Component scores
Mao 2015^51^ USA | 120 Breast cancer survivors ≥2 per day of bothersome severity 53.4 (3.4) | Electroacupuncture 10 treatments over 8 weeks | (1) Sham acupuncture 10 sessions over 8 weeks (2) Gabapentin 900 mg/day for 8 weeks (3) Placebo pill Gelatin capsules filled with lactose monohydrate | 8 and 24 weeks:; - Hot flash composite score; - Adverse events
Nedeljkovic 2014^53^ Switzerland | 40 Postmenopausal ≥20 per week 53.1 (3.5) | Acupuncture 12 weekly treatments | (1) Sham acupuncture, 12 weekly sessions (2) Chinese herbal medicine, 3 capsules twice daily and 4 clinic visits (3) Placebo, 3 capsules twice daily and 4 clinic visits | 12 and 24 weeks:; - Hot flash frequency; - Hot flash severity; - Menopause Rating Scale-II

a Menopause instruments and scales are described in Appendix D.

##### Risk of bias—New RCTs

All 4 new RCTs were judged to be low risk of bias. Risk of bias domains for the 4 RCTs are reported in Figure 2.

Figure 2 Risk of Bias Ratings for New Acupuncture RCTS^a^

^a^ A white bar indicates that the outcome was not reported.

#### Synthesis of Findings: Primary Outcomes

##### Vasomotor symptoms

###### Acupuncture versus no acupuncture or usual care

In the SR, Dodin et al^40^ conducted a meta-analysis of 3 trials that compared acupuncture with no acupuncture, the results of which demonstrated a statistically significant effect associated with acupuncture for both VMS frequency (SMD -0.50, 95% CI -0.69 to -0.31, I^2^ = 0.0%) and severity (SMD -0.54, 95% CI -0.73 to -0.35, I^2^ = 0.0%) compared with no acupuncture. Subgroup and sensitivity analysis were not performed. A meta-analysis reported in the review also suggests that quality of life, as assessed by the Women's Health Questionnaire, Menopausal Rating Scale, or the Menopause Specific Quality of Life Questionnaire, is improved with acupuncture (SMD -0.93, 95% CI -1.20 to -0.67, I^2^ = 32%, 3 trials) compared with no acupuncture. Each of the 3 trials included in these meta-analyses was judged by the authors of the SR to have low risk of bias for 5 of the 6 Cochrane Collaboration's Risk of Bias domains assessed. However, confidence intervals reported for pooled estimates of effect in this review are likely overly precise because Dodin et al did not use methods to account for small sample effects.^84^

We updated the meta-analysis reported in the SR by adding both the results at the end of treatment from Avis et al^52^ and the results of the waitlist control group at the end of treatment from the 3-arm RCT by Avis et al^80^ in the SR by Dodin (which was not included in the meta-analyses of acupuncture versus no acupuncture in that SR). Our updated meta-analysis generated an estimate of the SMD of -0.66 (95% CI -1.06 to -0.26; I^2^ = 61.7%, 5 trials) for reduction in VMS frequency (Figure 3) and SMD -0.49 (95% CI -0.85 to -0.13, I^2^ = 18.1%, 4 trials) for reduction in VMS severity (Figure 4). This translates to an average of 3 fewer hot flashes daily. Acupuncture resulted in a statistically significant decrease in hot flash frequency at 6 months that was maintained until 12 months after baseline.^52^

Figure 3 Forest Plot of Acupuncture versus No Acupuncture on Change in Hot Flash Frequency at End of Treatment

Figure 4 Forest Plot of Acupuncture versus No Acupuncture on Change in Hot Flash Severity at End of Treatment

###### Acupuncture versus sham acupuncture

Several different procedures designed to simulate the subjective experience of receiving an acupuncture treatment have been used as semi-inert comparisons to true acupuncture in the context of clinical trials. Dodin et al^40^ conducted meta-analyses using data from 8 trials^68,69,72,74,76,77,80,83^ that compared acupuncture to a sham control and reported daily VMS frequency or severity. These meta-analyses revealed no significant difference for daily VMS frequency (SMD -1.13, 95% CI -2.55 to 0.29; I^2^ = 70%) but significantly improved severity of hot flashes (SMD -0.45, 95% CI -0.84 to -0.05, I^2^ = 62%) compared with sham acupuncture. Subgroup analyses demonstrated that heterogeneity was partially explained by the trials involving women with breast cancer and trials with duration of treatment less than or greater than 12 weeks. Collectively, the 8 trials included in the meta-analyses had 37 low-risk, 3 high-risk, and 8 unclear risk of bias domains, as judged by the authors of the SR.

In the new RCT by Mao et al,^51^ electroacupuncture (which involves administering low-dose electrical current through some of the acupuncture needles) reduced the hot flash composite score at 24 weeks by 7.4 units, compared with 5.9 with sham electroacupuncture, 5.2 with gabapentin, and 3.4 with the placebo medication (p<0.001). In the new RCT by Ee et al,^50^ hot flash scores decreased in both groups by approximately 40% from baseline to end of treatment and were sustained for 6 months. There was no evidence of an advantage of electroacupuncture over sham acupuncture on quality of life. In the new RCT by Nedeljkovic et al,^53^ acupuncture was more effective than sham acupuncture in reducing hot flash frequency and severity, and in improving menopause-related quality of life.

We updated the meta-analysis reported in the SR by adding findings from these 3 new RCTs.^50,51,53^ Our updated meta-analysis generated an estimate of the SMD of -0.21 (95% CI -0.49 to 0.07, I^2^ = 53.5%, 10 trials) for reduction in VMS frequency (Figure 5) and -0.35 (95% CI -0.70 to 0.01, I^2^ = 66.5%, 8 trials) for reduction in VMS severity (Figure 6).

Figure 5 Forest Plot of Acupuncture versus Sham Acupuncture on Change in Hot Flash Frequency at End of Treatment

Figure 6 Forest Plot of Acupuncture versus Sham Acupuncture on Change in Hot Flash Severity at End of Treatment

In the 2 RCTs that assessed quality of life in the SR,^69,72^ no significant difference in quality of life (as assessed by the Menopausal Specific Quality of Life questionnaire or the Greene Climacteric Scale) was found between acupuncture and sham acupuncture (SMD 0.11, 95% CI -0.33 to 0.55). Our updated meta-analysis that included results of changes in the Menopause Specific Quality of Life questionnaire in 2 of the new RCTs^50,53^ generated an estimate of the SMD of -0.23 (95% CI -1.40 to 0.95, I^2^ = 77.0%, 5 trials) for change in quality of life (Figure 7).

Figure 7 Forest Plot of Acupuncture versus Sham Acupuncture on Change in Quality of Life at End of Treatment

###### Acupuncture versus hormone therapy

We did not identify new RCTs that compared acupuncture with hormone therapy. The SR, however, included 3 RCTs that compared acupuncture with hormone therapy.^81-83^ Among these, acupuncture was associated with significantly higher daily VMS frequency compared with hormone therapy (SMD 3.18, 95% CI 2.06 to 4.29, I^2^ = 0%, 3 trials). There was no statistically significant difference in VMS severity between acupuncture and hormone therapy (SMD 0.53, 95% CI -0.14 to 1.20, 2 trials). Two of these RCTs were judged to be of low risk for 4 of 6 domains, and one was judged to have 3 low-risk, 2 high-risk, and 1 unclear risk of bias domains. Quality of life as assessed by the Kupperman Index was significantly greater in the hormone therapy group than in the acupuncture group (MD 0.11, 95% CI 0.01 to 0.21, 1 trial) in the single study included in the review that reported this outcome.^82^

###### Acupuncture versus relaxation

We did not identify any new RCTs that compared acupuncture with relaxation. However, a single RCT^73^ included in the SR compared electroacupuncture with relaxation, finding no significant between-group differences for either daily VMS frequency (MD -0.40, 95% CI -2.18 to 1.38) or severity (MD 0.20, 95% CI -0.85 to 1.25). This RCT is discussed in greater detail in the Meditation, Relaxation, and Mindfulness section of this report.

#### Summary of Findings for Acupuncture

We found evidence that a course of acupuncture improves VMS and quality of life compared with no acupuncture, but not more than sham acupuncture. This suggests that acupuncture may be useful as an adjunct therapy and that the observed clinical benefits associated with acupuncture in the context of clinical trials may be attributable in part or in whole to nonspecific effects. We also found evidence that acupuncture may improve sleep quality, with one of the new RCTs demonstrating significant improvement in sleep compared with a waitlist control on 2 of 3 sleep outcome measures. There is inconclusive evidence of acupuncture's effectiveness in alleviating symptoms of depression or anxiety among women who experience menopause-related VMS. The only RCT included in our review that systematically assessed the safety of acupuncture relative to no acupuncture or medical management found that acupuncture was associated with significantly fewer adverse effects than gabapentin. To make these determinations, we drew from an existing, good-quality SR that included 15 pertinent trials and 4 new low risk of bias RCTs. Three of the 4 new RCTS found that reductions in Hot Flash Composite Score and hot flash frequency were maintained at 12, 16, and 24 weeks post-treatment, respectively.^51-53^

### YOGA, TAI CHI, AND QIGONG

#### Key Points

- We identified one eligible good-quality SR, published in 2012, that included 5 RCTs comparing yoga with inactive (waitlist) and/or active (exercise, stretching) comparators, and 2 new RCTs published since 2012 that assessed the impact of yoga on hot flash frequency, severity, and quality of life. We did not identify any eligible SRs or new RCTs that evaluated the effectiveness of tai chi or qigong.
- We conducted a meta-analysis examining the effect of yoga compared with active and inactive comparators on hot flash severity change scores using 2 new RCTs and 2 RCTs included in the SR. Meta-analysis results suggest that yoga is significantly associated with a reduction in hot flash severity (SMD -0.36, 95% CI -0.65 to -0.07, I^2^ = 0.0%).
- One RCT examined the effect of yoga versus control on quality of life; results were inconclusive due to the small study sample, but suggest that yoga may improve some measures of quality of life. Adverse effects were reported as an outcome in only one RCT and were infrequent.

#### Systematic Review

##### Study characteristics

We identified one good-quality SR by Cramer et al^43^ published in 2012 that included 5 RCTs^85-89^ (582 total participants) evaluating the effectiveness of yoga for bothersome menopause symptoms. Yoga interventions were delivered in 34 to 40 sessions over 8 weeks to 4 months. Outcomes included overall menopause symptoms and quality of life;^85-87^ VMS;^85,88,89^ psychological symptoms;^85-89^ and the adverse effects of yoga.^87^ Only one study^88^ examined the durability of treatment effects beyond end of treatment (at 12 weeks post intervention); this study only reported findings related to VMS using a daily diary (total score of hot flash frequency and severity) and not menopause symptoms or quality of life.

Authors of the SR^43^ conducted a meta-analysis for outcomes reported by more than 2 RCTs. Meta-analyses evaluated the effect of yoga compared with an active comparator and yoga compared with no treatment on (1) total menopause symptoms, (2) psychological symptoms, and (3) VMS. Subgroup meta-analyses also considered the effect of yoga versus an attention control and yoga versus no treatment separately on those 5 outcomes. One RCT was not included because it did not report sufficient data for quantitative analysis;^88^ all RCTs were included in the qualitative analysis.

Characteristics of the SR and included RCTs are summarized in Table 5.

Table 5 Study Characteristics: Cramer et al 2012^43^

Characteristic | Value
Systematic review
Number of included trials | 5
Number of patients | 582
Date of SR literature search | April 2012
Mean age range in years (median) | 45.6 to 54.9 (49.0)
RCTs included in the SR
Study years | 2007-2011
Countries
USA | 2
India | 2
Brazil | 1
Population
Perimenopausal or postmenopausal | 4
Women who had completed treatment for breast cancer | 1
Yoga interventions
Yoga postures | 5
Breathing | 4
Meditation | 5
Lifestyle lectures | 2
Planned number of yoga treatments | 34-40
Length of intervention period | 8 weeks to 4 months
Training of yoga instructors
Certified and experienced | 2
Not reported | 3
Comparisons
Inactive—waitlist | 4
Active—walking, stretching, lifestyle lectures | 3
Inactive and active (3-arm trial) | 2
Outcomes
Total menopause symptoms | 3
Vasomotor symptoms | 3
Psychological symptoms | 5
Sleep/insomnia | 0
Adverse effects of yoga | 1
Timing of last outcome assessment after randomization
Short-term (taken closest to 12 weeks after randomization) | 5
Long-term (taken closest to 12 months after randomization) | 1

##### Risk of bias—Systematic review

In the SR,^43^ risk of bias was assessed for each included RCT using the 12 criteria recommended by the Cochrane Back and Neck Review Group. RCTs that met 6 of the 12 criteria were rated as having low risk of bias. Of the 5 included RCTs, 2 were rated as low risk of bias^86,88^ and 3 as high risk of bias.^85,87,89^ Key issues included lack of blinding of participants or providers, inadequate intention-to-treat analysis, and inadequate disclosure of the full study protocol.

#### New Randomized Controlled Trials

##### Study characteristics

We identified 2 new RCTs published after 2012 that assessed the impact of yoga on VMS or quality of life among perimenopausal or postmenopausal women. Avis et al^54^ conducted a 3-arm trial comparing the effects of 10 weeks of integral yoga versus health-and-wellness education and waitlist control on frequency and severity of hot flashes. Ngowsiri et al^55^ conducted a trial comparing a 13-week Rusie Dutton course (which we determined to have similar components to yoga) with a waitlist control on menopause symptoms, including VMS. Outcomes examined among the 2 RCTs included VMS,^54,55^ health-related quality of life,^54^ psychological symptoms,^54,55^ and sleep disturbance.^54,55^ Yoga was compared with an attention health-and-wellness education control in one RCT^54^ and with an inactive waitlist control in both RCTs. Sample sizes were 54^54^ and 48.^55^ All participants were perimenopausal or postmenopausal. One RCT did not report cause of menopause or breast cancer history.^55^ Mean participant age ranged from 50.7 to 53.5 years. Yoga interventions included a combination of postures and breathing. One RCT included relaxation/meditation techniques in addition to yoga.^54^ The duration of yoga treatment ranged from 10 weeks to 13 weeks; sessions were held weekly for 90 minutes in both trials and all participants were encouraged to practice at home.

##### Outcome measures

In the 2 new RCTs, VMS was assessed using the Daily Hot Flash Diary (DHFD) at 5 and 10 weeks post-randomization^54^ and subscales from the MENQOL (Thai version) at 12 weeks post-randomization.^55^ Quality of life was measured using the Global Quality of Life scale at 5 and 10 weeks post-randomization and the Hot Flash Related Daily Interference Scale at 5 and 10 weeks post-randomization.^54^ Psychological symptoms were examined using the CESD-10 at 5 and 10 weeks post-randomization^54^ (Avis 2014) and subscales from the MENQOL at 12 weeks post-randomization (Ngowsiri 2014).^55^ Persistence of treatment effects beyond end of treatment was not examined in either study. Characteristics of the 2 new RCTs are summarized in Table 6.

Table 6 Study Characteristics of New RCTs

Study Country | Population # Women randomized Type of menopause # Hot flashes Mean age (range) | Intervention Category/type Session frequency/duration | Comparator Category/type Session frequency/duration | General Outcomes Instruments^a^
Avis 2014^54^ USA | Yoga: 18 Health and wellness: 19 Waitlist: 17 Natural; surgical; and women treated for breast cancer (not currently receiving treatment) ≥4 hot flashes per day on average for ≥4 weeks and ≥2 months since last menses Yoga: 53.5 (0.7) Health and wellness: 52.8 (0.7) Waitlist: 53.5(0.7) | Yoga: integral yoga, adapted from Satchidananda, with breathing, relaxation, and postures 1 group session per week for 10 weeks; 2-3 home practice per week for 15 minutes 90 minutes duration | Attention: health and wellness education 10 weekly educational classes; materials to read at home (to match time spent in home practice among individuals in intervention group) 90 minutes duration Inactive comparator: Waitlist; no initiation of new therapies for hot flashes or participation in classes for 10 weeks | - Frequency/severity of hot flashes (DDHF); - Sleep quality (Global Sleep Quality index); - Anxiety (HSCL); - Depressive symptoms (CESD); - Global quality of life (SF-36)
Ngowsiri 2014^55^ Thailand | Rusie Dutton: 24 Waitlist: 26 Type of menopause NR Mild to moderate menopause symptoms per Self-Assessment for Menopause Symptoms (developed from MRS) Yoga: 52.9 (4.3) Waitlist: 50.7 (3.6) | Yoga: Rusie Dutton 1 group class per week for 13 weeks; 2 home practice per week 90 minutes duration | Inactive comparator: Waitlist; offered class 13 weeks after post-test assessment was completed | Menopause specific quality of life subscales (Thai version of MENQOL subscales: vasomotor, psychological)

a Menopause instruments and scales are described in Appendix D.

##### Risk of bias—New RCTs

Both new RCTs were judged to be high risk of bias. Of primary concern was the use of a weak control (waitlist). Also, the study methods were not clearly described, including the method for random sequence generation, allocation concealment, and participant, provider, and assessor blinding (Figure 8).

Figure 8 Risk of Bias Ratings for New Yoga RCTs

#### Synthesis of Findings: Primary Outcomes

##### Vasomotor symptoms

###### Yoga versus inactive control

In the SR by Cramer et al, 2 studies examined the effect of yoga versus a waitlist control on VMS.^85,88^ The study by Carson et al was not included in the quantitative analysis because of incomplete reporting; therefore the SR did not conduct a meta-analysis that examined the effect of yoga compared with a waitlist control only on VMS. The Carson et al study was the only trial in the SR that examined the durability of treatment effect comparing yoga versus a waitlist control on VMS^88^; qualitative results suggest that the positive effects of yoga on VMS persisted at 12 weeks after the end of treatment (20 weeks post-randomization).

Our updated meta-analysis included data from the SR and both new RCTs. We summarized the findings of 3 RCTs that examined the effect of yoga compared with a waitlist control on changes in hot flash severity.^54,55,85^ These trials included the 3-armed trial^85^ identified in the SR, a newly identified 3-armed RCT that also included inactive and attention control arms,^54^ and another newly identified RCT that compared yoga with a waitlist control.^55^ We pooled the 3-arm trial samples and, unlike the SR, analyzed them as part of the inactive control comparator subgroup analysis. In our meta-analysis, we found no effect of yoga (3 trials; SMD -0.34, 95% CI -0.92 to 0.25, I^2^ = 0.0%) (Figure 9).

Figure 9 Forest Plot of Yoga versus Control on Change in Hot Flash Severity at End of Treatment

###### Yoga versus attention control

Authors of the SR conducted a meta-analysis of 2 RCTs; one compared yoga with an attention control^89^ and the other, a 3-armed trial, included an attention and inactive control.^85^ Only data from the attention control arm was used; the analysis examined yoga versus an attention control and found that, compared with exercise, stretching, and lifestyle discussions, yoga was not associated with a reduction in VMS (2 trials, SMD -0.13, 95% CI -0.58 to 0.33, I^2^ = 67%).^85,89^

For one of the new RCTs^54^ – a 3-arm trial (yoga vs waitlist control vs health-and-wellness education attention control) – the data from the 2 control arms were pooled and analyzed as part of the inactive comparator subgroup analysis. In this trial,^89^ yoga was more effective than the waitlist and attention control arms combined (SMD -0.40, 95% CI -0.78 to -0.02) (Figure 9).

###### Overall effect of yoga versus all controls

Of the 2 new RCTs, one found significant differences in vasomotor pre/post scores on the MENQOL Thai version subscale (p = 0.04).^55^ The other RCT did not find any statistically significant effects of yoga on VMS (Table 6).^54^ We updated the meta-analysis in the SR by adding data reported in the 2 new RCTs^54,55^ to assess the effect of yoga on changes in hot flash severity. We included inactive (waitlist)^54,55,85^ and attention (health-and-wellness education and exercise) controls;^54,89^ attention and inactive controls were pooled. We found that yoga was associated with an overall statistically significant decrease in hot flash severity (4 trials, SMD -0.36, 95% CI -0.65 to -0.07, I^2^ = 0.0%) (Figure 9).

In the SR,^43^ authors conducted a meta-analysis of 2 RCTs^85,89^ and found that yoga compared with exercise^89^ and waitlist control^85^ was not associated with short-term benefits for VMS (2 trials, SMD -0.04, 95% CI -0.68 to 0.60, I^2^ = 81%). The effects were inconsistent across the 2 RCTs: one showed a small benefit and the other showed a small harm, but in both, the effect size was not statistically significant. However, in one RCT that included a longer-term follow-up (20 weeks) for yoga compared with no treatment, significant effects were found for VMS.^88^

##### Health-related quality of life

Of the 5 RCTs identified by the SR, only one RCT used a scale (the Greene Climacteric Scale) that by our judgment assessed the concept of health-related quality of life,^85^ which was conceptualized as total menopause symptoms in the SR. The other 2 RCTs that assessed total menopause symptoms used the Kupperman Index^87^ and the Menopause Rating Scale.^86^ In an RCT comparing yoga with a walking attention control and a waitlist control,^85^ yoga was not found to have an impact on quality of life. Of the 2 new RCTs, one did not assess quality of life^55^ and the other used the SF-36 and found no effect of yoga on quality of life.^54^

#### Summary of Findings for Yoga

We identified 1 good-quality SR and 2 new RCTs that examined the effect of yoga on bothersome menopause symptoms and quality of life. In general, RCTs demonstrated inconsistent effects of yoga for reducing VMS and increasing quality of life. Meta-analysis results from the SR suggest that short-term effects of yoga are not significantly associated with changes in VMS. However, results from our meta-analysis suggest that yoga is associated with a decrease in hot flash severity. Our results likely differ from those in the SR because of the addition of the 2 new RCTs and because we used a treatment effect that adjusted for baseline differences in symptom severity.^85^ Yoga demonstrated no impact on quality of life.

### STRUCTURED EXERCISE

#### Key Points

- We identified 2 SRs (1 good quality and 1 fair quality) that met our eligibility criteria. One SR focused exclusively on exercise for the frequency and severity of hot flashes among perimenopausal and postmenopausal women, and the other SR included evaluations of exercise and mindfulness and relaxation. All of the studies in the good-quality SR were included in the fair-quality SR.
- In the good-quality SR, no statistical evidence was found to support exercise versus control (n = 4 studies) or exercise versus yoga (n = 2 studies). One RCT (n = 14) included in this SR found hormone therapy to be statistically superior to exercise.
- We identified 2 new RCTs that examined exercise for VMS frequency and severity of hot flashes among perimenopausal or postmenopausal women. One of these included only women after breast cancer treatment. Both RCTs were judged to be low risk of bias.
- Our new meta-analysis compared exercise as an intervention for hot flash frequency and severity. We found that exercise did not produce a significant effect on either hot flash frequency (SMD -0.08, 95% CI -0.33 to 0.16, I^2^ = 0.0%, 4 trials) or severity (SMD -0.06, 95% CI -0.21 to 0.10, I^2^ = 0.0%, 5 trials).
- One new RCT reported on the outcome of menopause-specific quality of life and found significantly lower sleep problem scores at the 6-month follow-up. The other new RCT measured overall health-related quality of life and reported moderate benefit on short-term (effect size 0.46) and long-term (effect size 0.41) physical function outcomes. A companion study reported that exercise significantly improved sleep quality and decreased hot flashes during sleep.
- One RCT reported on adverse events, finding no serious adverse events and no differential incident adverse events between the exercise and control groups.

#### Systematic Reviews

##### Study characteristics

We identified 2 eligible SRs evaluating the effectiveness of structured exercise for VMS and quality of life.^44,46^ The good-quality SR by Daley et al^44^ published in 2014 included 5 RCTs evaluating the effectiveness of structured exercise for menopausal hot flashes.^85,90-93^ The fair-quality SR by Woods et al^46^ published in 2014 included 4 RCTs that were not included in the SR by Daley et al. Of those, 3 were excluded by Daley et al because women were not symptomatic at baseline, and one was excluded because participants were taking hormone therapy at baseline. Two RCTs^85,92^ were included in both SRs.

For the purposes of this report, we focus only on the good-quality Cochrane Collaboration SR by Daley et al^44^ because it included more studies, employed more inclusive eligibility criteria, contained a meta-analysis of studies, and was of higher quality. In this SR, sample sizes of the 5 included RCTs ranged from 37 to 355. The population was middle-aged women with VMS. Most studies required women to be sedentary or at low activity levels at baseline. Hormone therapy was restricted in most studies (n = 3) to the previous 2 months to 6 months. The comparator in most studies was an inactive control (n = 4) or yoga (n = 2).

A total of 762 women were enrolled across the 5 RCTs with an age range of 40 to 63 years. Three of the 5 RCTs were 3-arm trials resulting in a total of 8 comparators. Comparisons in most studies were made between inactive controls (n = 4) or yoga (n = 2). The outcome was VMS frequency and severity for all 5 RCTs with only one study reporting adverse effects. The majority of the RCTs included symptomatic perimenopausal or postmenopausal women (n = 4), with one RCT including women with surgically removed ovaries. In the majority of studies (n = 4) exercise was conducted with supervision or in a group session. The number of planned sessions and length of the intervention period varied greatly from 12 to 96 weeks and 12 to 36 weeks, respectively. Only 2 RCTs used a certified or trained exercise instructor during the exercise sessions. The majority of studies were short-term (≤12 weeks).

Authors of the SR^44^ conducted a meta-analysis using random-effects models when 2 or more RCTs reported the same outcomes. The primary outcome was frequency and severity of VMS and the secondary outcome was adverse effects of the intervention. For the primary outcome, summary estimates were generated for exercise compared with no treatment or control (n = 3 studies)^85,90,91^ and exercise compared with yoga (n = 2 studies).^85,91^ Qualitative analysis was conducted for one RCT^93^ that compared structured exercise with hormone therapy and for one RCT in which the authors determined that insufficient data were provided to be included in the meta-analysis. For the secondary outcome, qualitative analyses were provided for one RCT that included data on adverse events of the intervention.

Characteristics of the SR and included RCTs are summarized in Table 7.

Table 7 Study Characteristics: Daley et al 2014^44^

Characteristic | Value
Systematic review
Number of included trials | 5
Number of patients | 762
Date of SR literature search | March 2014
Mean age range in years (median) | 40-63
RCTs included in the SR
Study years | 2002-2011
Countries
Iran | 1
Finland | 1
Sweden | 1
USA | 2
Population
Perimenopausal or postmenopausal | 4
Women who had completed treatment for breast cancer | 0
Women who had ovaries surgically removed | 1
Exercise interventions
Exercise unsupervised | 1
Exercise with supervision | 2
Exercise in a group | 2
Planned number of exercise treatments | 12 to 96
Length of intervention period in weeks | 12 to 36
Training of exercise instructors
No instructor or supervision | 2
Certified and trained | 2
Not reported | 1
Comparisons
Inactive control | 5
Active (yoga or hormone therapy) | 3
Outcomes
Hot flash frequency and severity | 5
Adverse effects | 1
Timing of last outcome assessment after randomization
3 months | 3
6 to 9 months | 2 (6 and 9 months)

##### Risk of bias—Systematic review

In the SR,^44^ risk of bias was assessed for each included RCT using the Cochrane Risk of Bias Tool. The risk of bias was judged to be high among 4 RCTs^85,90,92,93^ and low in one.^91^ Key issues included unclear specification of sequence generation (n = 2 studies), unclear outcome assessment blinding (n = 3 studies), high attrition rate (n = 1 study), and incomplete data reporting (n = 2 studies).

#### New Randomized Controlled Trials

##### Study characteristics

We identified 2 relevant RCTs that were not included in the SR by Daley et al.^62,63^ Both compared exercise with an inactive control. One RCT^62^ was published in 2015 after the SR, and the other,^63^ published in 2012, was not included in the SR because it evaluated only women who had primary breast cancer. The new RCT by Daley et al^62^ was a 3-arm trial randomizing participants to (1) exercise and DVD support, (2) exercise and community-based social support, or (3) inactive control. The outcomes were measured at both 6 months (immediately following completion of the intervention) as well as at 12 months' post-randomization. The 2 exercise intervention groups consisted of face-to-face consultations with a physical activity facilitator, with one of the groups additionally receiving a DVD of menopause education and written materials to encourage regular exercise.

The RCT by Duijts et al^63^ was a 4-arm trial randomizing participants to (1) exercise alone, (2) exercise plus cognitive behavioral therapy, (3) cognitive behavioral therapy alone, or (4) a waitlist control group. The exercise program was a 12-week, individually tailored, home-based, self-directed exercise program of 2.5 to 3 hours per week. A primary outcome for both of these studies was hot flash frequency and severity. Outcomes were measured at both 12 weeks (immediately following completion of the intervention) as well as at 6 months post-randomization.

Among both RCTs, there were 576 participants; all were perimenopausal or postmenopausal. One RCT^63^ included only women with primary breast cancer not currently on cancer treatment but experiencing VMS. The other^62^ included women with VMS who were not receiving hormone therapy in the past 3 months. Mean participant age ranged from 47.7 to 57.7 years. Exercise interventions were group sessions^63^ and individually tailored programs,^62^ with both studies focusing on aerobic exercise. The intervention in one RCT^63^ included one treatment arm with cognitive behavioral therapy and a treatment arm with combined cognitive behavioral therapy and exercises; for the purposes of this review, it was excluded from the meta-analysis. The exercise intervention in the other RCT^62^ included supplemental DVD education in one arm and social support in the other arm. We combined these 2 arms and compared them against the control group in our updated meta-analysis because we were primarily concerned with the efficacy of exercise. From both RCTs, the duration of exercise interventions ranged from 12 weeks to 24 weeks; sessions were held weekly for 40 to 90 minutes, and all participants were encouraged to exercise at home on their own.

##### Outcome measures

In both new RCTs, VMS was assessed using the Hot Flush Rating Scale. Outcomes were assessed at 6 and 12 months post-randomization^62^ and at 12 weeks and 6 months follow-up.^63^ One RCT included generic health-related quality of life measured with the SF-36 Short Health Assessment Form as a secondary outcome^63^ and the other RCT included menopause-specific quality of life using subscales from the Women's Health Questionnaire as a secondary outcome.^62^

Characteristics of the 2 new RCTs are summarized in Table 8.

Table 8 Study Characteristics of New RCTs

Study Country | Population # Women randomized Type of menopause # Hot flashes Mean age (range) | Intervention Category/type Session frequency/duration | Comparator Category/type Session frequency/duration | General Outcomes Instruments^a^
Duijts 2012^63^ Netherlands | Exercise + CBT: 106 Exercise: 104 Waitlist: 103 Primary breast cancer and not currently on treatment 2 or 3 VMS symptoms “sometimes” or 1 “often” in previous 2 weeks Exercise + CBT: 49.0 Exercise: 47.7 Control: 47.8 | Cognitive behavioral therapy; 6 weekly group sessions of 90 minutes, including relaxation exercises Physical exercise: 12 weeks, individually tailored, home-based, self-directed program of 2.5 to 3 hours per week | Waitlist control with no instructions | - Hot flashes and night sweats measured using Hot Flush Rating Scale; - Generic quality of life measured using SF-36 Short Form Health Survey
Daley 2015^62^ Thailand | Exercise + DVD: 87 Exercise + social support: 87 Control: 87 Perimenopausal and postmenopausal women experiencing ≥ 5 hot flashes/night sweats per day and have not taken hormone therapy in previous 3 months Exercise + DVD: 52.3 (2.4) Exercise + social support: 52.7 (2.5) Control: 52.0 (2.4) | Both intervention groups: 2 face-to-face consultations with a physical activity facilitator to support engagement in regular exercise Exercise + DVD group received a menopause-specific information DVD and written materials to encourage regular exercise Exercise + support group offered opportunity to attend exercise social support groups in their communities | Inactive comparator (control) offered the opportunity to have an exercise consultation and were given a pedometer at the end of their involvement in the study | - Hot flashes and night sweat frequency measured using Hot Flush Rating Scale; - Menopause-specific quality of life subscales from the Women's Health Questionnaire

a Menopause instruments and scales are described in Appendix D.

##### Risk of bias—New RCTs

Both new RCTs were judged to be low risk of bias. Of primary concern in one RCT was the use of a weak control and poor compliance with the intervention.^62^ Both studies had high or unclear risk of bias for items related to blinding of the intervener or the participant. However, studies using exercise as an intervention are commonly unable to implement blinding and therefore comments and ratings should be interpreted in light of these constraints (Figure 10).

Figure 10 Risk of Bias Ratings for New Structured Exercise RCTs^a^

^a^ A white bar indicates that the outcome was not reported.

#### Synthesis of Findings: Primary Outcomes

##### Vasomotor symptoms

###### Structured exercise versus inactive control

In the SR, 4 RCTs were evaluated that compared structured exercise with an inactive control.^85,90,91,93^ Three of the these were included in a meta-analysis; one^93^ was excluded due to inadequate reporting of the control group. The random-effects meta-analysis of the other 3 RCTs demonstrated no significant effect of exercise on the outcome of frequency or severity of VMS when compared with no treatment or control. The RCT excluded in this meta-analysis^93^ included 37 women and reported a significant decrease (p<0.05) in hot flash scores in the exercise plus soy milk group compared with control.

Our updated meta-analysis provided separate pooled estimates for hot flash frequency and severity. We summarized 3 RCTs^85,90,91^ from the SR examining a change in hot flash frequency plus one new RCT^62^ assessing a follow-up for hot flash frequency. Effects were fairly consistent and studies were homogeneous; however, we found no statistical evidence that exercise decreased hot flash frequency when compared with no treatment or control (SMD -0.08, 95% CI -0.33 to 0.16, I^2^ = 0.0%, 4 trials) (Figure 11). Only one study, the new RCT by Daley et al,^62^ measured hot flash frequency at 12 months, 6 months following end of treatment, finding no significant difference between the intervention arm and control arm. For hot flash severity, we summarized 3 RCTs^62,63,85^ on follow-up in hot flash severity and 2 RCTs^90,91^ on a change in hot flash severity. Again, effects were fairly consistent and studies were homogeneous; however, we found no statistical evidence that exercise decreased hot flash severity when compared to no treatment or control (SMD -0.07, 95% CI -0.26 to 0.13, I^2^ = 1.8%, 3 trials) (Figure 12). Both Duijts et al and Daley et al followed participants after the end of treatment, showing no significant durability of effect for exercise as an intervention for hot flash severity.

Figure 11 Forest Plot of Exercise versus Control on Change in Hot Flash Frequency at End of Treatment

Figure 12 Forest Plot of Exercise versus Control on Change in Hot Flash Severity

###### Structured exercise versus yoga

Authors of the SR^44^ identified 2 RCTs that compared structured exercise with yoga.^85,91^ In a random-effects meta-analysis no evidence was found that structured exercise was significantly better than yoga for reducing a combined frequency or severity score for hot flashes (SMD 0.03, 95% CI -0.45 to 0.38, I^2^ = 61%, 2 trials).

###### Structured exercise versus hormone therapy

Only one RCT was identified in the SR evaluating structured exercise compared with hormone therapy.^92^ This RCT reported a larger reduction in the frequency of hot flashes per 24 hours in the hormone treatment group than in the exercise group (mean difference 5.80, 95% CI 3.17 to 8.43) among 14 participants at a 12-week follow-up.

##### Sensitivity analyses

Authors of the SR^44^ found that exclusion of the single low risk of bias RCT did not affect the overall findings for any outcome.

#### Summary of Findings for Exercise

Overall, there were 7 RCTs evaluating exercise as an intervention among perimenopausal or postmenopausal women experiencing hot flashes. Five of these were identified in one good-quality SR with a meta-analysis examining the effect of exercise on the frequency and severity of hot flashes among perimenopausal or postmenopausal women.^44^ We also identified 2 new RCTs and conducted a new meta-analysis separating the outcomes of hot flash frequency and severity.^62,63^ The meta-analysis conducted in the SR along with our meta-analysis indicated no significant effect of exercise for decreasing hot flash frequency or severity. Statistically significant findings were shown in 2 new RCTs for the secondary outcomes of generic health-related quality of life^63^ and menopause-specific quality of life.^62^ A companion follow-up paper indicated that exercise significantly improved sleep quality and decreased hot flashes during sleep. Only one RCT reported adverse events, finding no serious or differential adverse events between exercise and control groups.^91^ The sample sizes of included studies in the SR were small, many of the primary studies included in the SR were judged to be of low quality, and few studies addressed long-term outcomes. The new RCTs were of greater sample size and judged by our group to be low risk of bias^63^ and unclear risk of bias.^62^ We conclude that the there is no evidence that structured exercise is beneficial over an inactive control for the outcomes of VMS frequency or severity, and limited evidence suggests that exercise is not beneficial over an active comparator or hormone therapy.

### MEDITATION, MINDFULNESS, HYPNOSIS, AND RELAXATION

#### Key Points

- We identified 5 SRs (2 good quality, 3 fair quality) that met eligibility criteria. Four SRs examined relaxation and mindfulness. Three of these reported on trials of multiple types of interventions. One examined hypnosis exclusively.
- No significant difference in reduction of hot flash frequency was found between any types of relaxation or mindfulness interventions compared with control groups for the primary outcomes of VMS frequency or quality of life. One small RCT found that severity of hot flashes decreased more in a modified applied relaxation training group compared with traditional applied relaxation. One trial of mindfulness-based stress reduction compared with a waitlist control found significant improvements in anxiety and sleep quality. However, the quality of evidence overall was poor.
- One fair-quality SR included 3 RCTs examining the impacts of hypnosis on breast cancer-related symptoms, including hot flashes, and found a significant decrease in hot flashes compared with no treatment (effect size ranged from 0.479 to 1.25), but no difference with hypnosis when compared to an active control (gabapentin).
- We identified 6 new RCTs that were not included in existing SRs. Three RCTs examined paced respiration and 3 examined applied relaxation. Overall, the quality of these new studies was mixed.
- We conducted 2 new meta-analyses examining 4 RCTs comparing paced respiration with a control group. We found that paced respiration is not associated with a statistically significant decrease in hot flash frequency (SMD 0.04, 95% CI -0.73 to 0.82, I^2^ = 56.6%, 3 trials) or severity (SMD 0.06, 95% CI -0.69 to 0.80; I^2^ = 65.1% 3 trials).

#### Systematic Reviews

##### Study characteristics

We identified 5 eligible SRs evaluating the effectiveness of meditation, mindfulness, or relaxation interventions for bothersome menopause symptoms.^45-49^ Of these, one good-quality SR focused solely on relaxation,^45^ and one fair-quality SR focused solely on hypnosis,^49^ while the other 3 evaluated multiple interventions.^46-48^ Of the latter SRs, one was good quality^48^ and 2 were fair quality.^46,47^

For the purposes of this report, we focus on the 2014 Cochrane Collaboration SR by Saensak et al^45^ addressing relaxation, and on the 2015 SR by Cramer et al,^49^ which presented qualitative findings only of studies that examined hypnosis. We include findings from the latter primarily because it was the only SR available on this intervention type. The other fair-quality SRs evaluated additional studies that were not included in our 2 prioritized SRs, but the individual studies were generally of poor quality. One unique RCT evaluating relaxation^94^ was included in the good-quality SR^48^ of multiple interventions and is noted in our synthesis. Only one RCT evaluating mindfulness-based stress reduction^95^ was identified and it was described in 2 of the fair-quality SRs.

The good-quality SR from 2014^45^ by Saensak et al included 4 RCTs^96-99^ comparing relaxation-based interventions and either nontreatment or other nonhormonal treatments. The authors focused on identifying relaxation techniques that were based on physiological principles of either somatic or cognitive relaxation, or both. These included more commonly known types of relaxation techniques such as paced respiration and muscle relaxation, though the authors also looked for a wide variety of relaxation approaches. Six databases and the grey literature were searched through February 19, 2014. The 4 RCTs included 281 menopausal women ranging in age from 30 to 77 years. Women were included if their last menstrual period was at least 6 months ago,^98^ and one RCT was limited women to those whose last menstrual period was at least 12 months ago.^97^ Menopausal status was confirmed with labs including follicle-stimulating hormone and estradiol levels in 2 RCTs.^98,99^ Two RCTs targeted women with primary breast cancer who were bothered by hot flashes, one of which specified that women taking aromatase inhibitors or hormone therapies other than tamoxifen were included.^96,98^ The reason for menopause onset (spontaneous versus surgical) was not specified in one study.^99^

VMS status in these RCTs was described as follows: one trial specified hot flashes that were troublesome,^96^ one trial required at least 5 hot flashes per day,^97^ one trial required at least 2 hot flashes per 24 hour period,^98^ and one trial required hot flashes severe enough to request treatment.^99^ Outcomes studied included VMS frequency per 24 hours (n = 3),^97-99^ Kupperman Index (n = 2),^96,98^ and mood (n = 1)^96^; no studies reported on quality of life or adverse effects. Two RCTs included in the SR reported duration of treatment sessions and number of sessions planned.^98,99^ In both of those, the applied relaxation arms received 12 weekly training sessions of 60 minutes per session. Duration and frequency of relaxation treatments in the other 2 RCTs were not reported. Only one of the 4 trials included in the SR assessed the durability of treatment effects, reporting outcomes 12 weeks after completion of the intervention.^98^ Final follow-up visit data from this trial and that from a second trial of relaxation^99^ were pooled despite differences in time since baseline.

Characteristics of this SR and included RCTs are summarized in Table 9.

Table 9 Study Characteristics: Saensak et al 2014^45^

Characteristic | Value
Systematic review
Number of included trials | 4
Number of patients | 281
Date of SR literature search | February 2014
Age range in years | 30 to 77
RCTs included in the SR
Study years | 1992-2008
Country, number of studies
Sweden | 2
United Kingdom | 1
United States | 1
Population
Excluded women who had stopped hormone therapy within 6 months | 2
Surgical menopause allowed | 3
Breast cancer patients | 2
Interventions
Paced respiration | 1
Applied relaxation | 3
Planned number of sessions
12 sessions of 60 minutes | 2
Not reported | 2
Duration of intervention
4 weeks | 1
12 weeks | 3
Training of instructors
Not reported | 4^a^
Comparisons
Control | 1
Electro acupuncture | 1
Superficial needle insertion/electroacupuncture/oral estrogen | 1
Alpha-wave biofeedback | 1
Outcomes
VMS frequency per 24 hours | 3
Quality of life | 0
Menopause-related quality of life | 2
Mood | 1
Adverse effects | 0
Timing of last outcome^b^
4 weeks | 2
6 months | 1

a No restriction was placed on training type of person delivering intervention.

b Timing of outcomes for one RCT was not reported.

The fair-quality SR from 2015^49^ included 13 RCTs examining hypnosis among women with breast cancer, women who were survivors of breast cancer, women undergoing diagnostic breast biopsy, and postmenopausal women without a history of breast cancer. Five databases were searched from inception through February 25, 2014, as well as a review of bibliographies. Of the 13 RCTs, 3 were relevant to our review and included a total of 274 women.^100-102^ One RCT compared hypnosis with attention control among 187 postmenopausal women.^100^ One compared hypnosis with no treatment among breast cancer survivors (n = 60)^101^; and one compared hypnosis with moderate-dose gabapentin in breast cancer survivors and women at increased risk of developing breast cancer (n = 27).^102^ Outcomes measured by these RCTs included VMS frequency (n = 2),^100,102^ health-related quality of life (n = 3),^100-102^ mood (n = 1),^101^ and adverse effects (n = 2).^100,102^ Timing of follow-up assessments during these RCTs was not clearly stated.

Characteristics of this SR and included RCTs are summarized in Table 10.

Table 10 Study Characteristics: Cramer et al 2015^49^

Characteristic | Value
Systematic review
Number of included trials | 3
Number of patients | 274
Date of SR literature search | February 2014
Age range in years | 54.5 to 58.2^a^
RCTs included in the SR
Study years | 2008-2013
Country, number of studies
United States | 3
Population
Breast cancer survivors | 2
Postmenopausal women without a breast cancer history | 1
Interventions
Hypnosis | 3
Planned number of sessions
5 weekly sessions | 2
3 weekly sessions | 1
Duration of intervention
3 to 5 weeks | 3
Training of instructors
Not reported | 3^b^
Comparisons
No treatment | 1
Attention control | 1
Gabapentin | 1
Outcomes
VMS frequency | 2
Health-related quality of life | 3
Mood | 1
Adverse effects | 2
Timing of last outcome
Not reported | 3

a One study did not report mean age of participants.

b No restriction was placed on training type of person delivering intervention.

Saensak at al^45^ pooled the data from 2 RCTs for a meta-analysis comparing the effectiveness of relaxation versus acupuncture.^98,99^ Too few studies were identified for additional sensitivity analysis. Cramer et al^49^ presented only qualitative descriptions of included studies. None of the other SRs conducted any meta-analyses; instead, results of comparisons were described qualitatively.

##### Risk of bias—Systematic reviews

In the SR by Saensak et al,^45^ authors did not report an overall risk of bias rating for individual studies. They noted that the overall quality of the evidence was “very low,” implying high risk of bias. Concerns included lack of data, imprecision, failure to report methods adequately, and 2 RCTs whose data were not suitable for meta-analysis. They also noted that the included RCTs did not report important outcomes of interest including adverse events, night sweats, and sleep disturbances.

The SR by Cramer et al^49^ reported that, overall, the studies they included had a low risk of bias using the Cochrane Risk of Bias tool.^33^ However, in the risk of bias assessment for the 3 relevant studies for our review, one was noted to be at high risk for performance, detection, attrition, and other biases.^102^ The second RCT was at unclear risk of performance and detection bias and high risk of reporting bias.^101^ The third RCT was at unclear risk of selection, performance, and detection bias.^100^

#### New Randomized Controlled Trials

##### Study characteristics

We identified 6 relevant RCTs not included in the previous SRs that assessed the impact of meditation, mindfulness, hypnosis, or relaxation interventions on VMS or quality of life among perimenopausal or postmenopausal women.^56-61^ Of the 6 RCTs, 3 examined paced respiration^56,57,60^ and 3 examined applied relaxation.^58,59,61^ We did not find any new RCTs on hypnosis. There was a total of 650 participants across the 6 RCTs, 446 for comparisons of paced respiration and 177 for relaxation.

Characteristics of the 6 new RCTs are summarized in Table 11.

Table 11 Study Characteristics of New RCTs

Study Country | Population # Women randomized Type of menopause # Hot flashes Mean age in years (range) | Intervention Category/type Session frequency/duration | Comparator Category/type Session frequency/duration | General Outcomes Instruments^a^
Paced respiration
Carpenter 2013^56^ USA | 218 Mixed population^a^ ≥2 hot flashes per day of moderate or greater severity 53.44 (6.84) | Paced respiration Home-based practice 15 minutes twice daily | Attention control: fast shallow breathing Twice daily Usual care: waitlist | - Hot flash frequency; - Hot flash severity; - Profile of Mood States-short form; - Pittsburgh Sleep Quality Index; - Adverse events
Huang 2015^57^ USA | 123 Perimenopausal or postmenopausal ≥4 per day 53.4 (3.4) | Paced respiration Brief, in-person instruction (<15 minutes); ≥15 minutes per day home practice | Attention control: music listening Brief, in-person instruction (<15 minutes); ≥15 minutes per day home practice | - Hot flash frequency; - Hot flash severity; - Menopause quality of life; - Insomnia Severity Index; - Beck Depression Inventory; - Hospital Anxiety and Depression Scale
Sood 2013^60^ USA | 105 Mixed population^b^ ≥14 per week, at least 1 month prior to enrollment 51 | Paced breathing (2 arms) Initial in-person instruction: (1) 15 minutes once daily and (2) 15 minutes twice daily | Attention control: usual breathing Initial in-person instruction; 10 minutes per day | - Hot flash frequency; - Hot flash severity; - Profile of Mood States; - Pittsburgh Sleep Quality Index; - Adverse effects
Applied relaxation
Lindh-Astrand 2015^61^ Sweden | 46 Postmenopausal ≥7 moderate/severe per 24 hours Mean age: NR | Applied relaxation, internet-delivered 10 weeks; 9 weekly modules via group sessions Instructional CD | Untreated control | 10 weeks:; - Hot flash frequency
Lindh-Astrand 2013^58^ Sweden | 60 Postmenopausal ≥7 moderate to severe per 24 hours Applied relaxation: 54.0 (5.7) Control: 56.0 (5.1) | Applied relaxation 10 therapist-led group sessions over 12 weeks; 60 minutes per session Home practice | Untreated control: waitlist control | 12 weeks:; - Hot flash frequency; - Women's Health Questionnaire:; - Sleep subscale; - Adverse events
Saensak 2013^59^ Thailand | 71 Perimenopausal and postmenopausal women^c^ ≥ Hot flash severity score Modified relaxation: 49.8 (3.8) Applied relaxation: 52.5 (5.1) | Applied relaxation, modified relaxation version One 60-minute session of therapist-led training; daily home practice of 15-20 minutes per day at least 5 days per week Weekly phone contact with therapist | Applied relaxation: Conventional 12 weekly sessions of therapist-led training; 60 minutes per session; daily home practice; weekly phone contact with therapists | 12 weeks:; - Hot flash frequency; - Hot flash severity; - Sleep disturbance

a Menopause instruments and scales are described in Appendix D.

b Mixed population includes those with and without a history of breast cancer.

c Surgical or natural.

##### Risk of bias—New RCTs

Of the 6 new RCTs that we identified, one was judged to be at high risk of bias,^61^ 2 at unclear risk of bias,^58,60^ and 3 at low risk of bias^56,57,59^ (Figure 13). For the new RCTs of paced respiration, there were 2 low risk^56,57^ and one at unclear risk.^60^ Of the 3 new relaxation RCTs, one was low risk,^59^ one was unclear risk,^58^ and one was high risk.^61^ The one study at high risk was stopped prematurely due to an unacceptably high dropout rate (>60%). There were concerns regarding blinding of participants in all new RCTs except for one,^59^ which was comparing 2 versions of applied relaxation. Similar to other types of interventions considered in this review, it is not uncommon to be unable to fully blind participants in relaxation, mindfulness, or hypnosis interventions. Another common concern among these trials was the measurement of self-reported outcomes among participants who were unblinded or incompletely blinded. Again, this concern is shared across all the intervention types included in this review.

Figure 13 Risk of Bias Ratings for Meditation, Mindfulness, Hypnosis, and Relaxation New RCTs^a^

^a^ A white bar indicates that the outcome was not reported.

#### Synthesis of Findings: Primary Outcomes

For the primary outcomes of VMS and quality of life, we have organized the findings by intervention type (ie, meditation, mindfulness, hypnosis, and relaxation). We focus on findings from the good-quality SRs – Saensak et al^45^ and Rada et al^48^ – and supplement by using results from the new RCTs as applicable.

##### Meditation

We did not find an SR that addressed meditation, nor did we identify any recently published RCTs on this intervention type for treatment of VMS in perimenopausal or postmenopausal women.

##### Mindfulness

We did not find an SR that addressed mindfulness specifically, nor did we identify any recently published RCTs on this intervention type. One RCT^95^ included in the fair-quality SR by Woods et al^46^ compared mindfulness-based stress reduction with a waitlist control. In this trial of 110 women (mean age 53.1 years), there was no difference between groups in hot flash frequency or intensity. This same study noted that women in the mindfulness-based stress reduction group did experience significant improvements (p<0.01) in sleep quality and anxiety compared with a waitlist control at 9 weeks.

##### Hypnosis

Based on one fair-quality SR by Cramer et al^49^ that included 3 trials of hypnosis on women with a history of breast cancer and those with hot flashes in the setting of menopause, there is evidence of a significant decrease in hot flashes compared with no treatment (effect size ranged from 0.479 to 1.25), though no difference for hypnosis was found compared with treatment with gabapentin.^100-102^

###### Active comparators

One RCT (n = 27) in Cramer et al^102^ compared hypnosis with 900mg daily of gabapentin among breast cancer survivors and those at increased risk for breast cancer. Authors found that the median number of hot flashes decreased in both arms (80% versus 33.3% respectively), though the between-group difference was not statistically different. A similar reduction in hot flash severity as reported by the Hot Flash Severity Score in both arms was similarly not significant between groups.

###### Inactive comparators

The 2 RCTs^100,101^ comparing hypnosis with no treatment/attention control in Cramer et al^49^ found that hypnosis led to a larger decrease in hot flashes than no treatment/attention control, with effect sizes of 0.479 (p < 0.001) in one RCT of breast cancer survivors,^101^ and 0.52 to 1.25 (p < 0.001) in an RCT of postmenopausal women without a history of breast cancer.^100^

##### Relaxation

The evidence, based on findings from the 4 RCTs in Saensak et al^45^ plus one RCT from the multiple intervention SR by Rada et al^48^ along with 6 of the new RCTs we identified,^56-61^ does not support a significant reduction in hot flash frequency with relaxation techniques versus comparator interventions or placebo. One new RCT (n = 60)^58^ noted a significant decrease in hot flash frequency among women treated with applied relaxation compared with control at 12 weeks (5.0 fewer hot flashes/24 hours compared with 1.9 fewer hot flashes/24 hours respectively [P<0.001]).

We conducted a new meta-analysis of 3 new RCTs^56,57,60^ plus one RCT^97^ included in the Saensak et al SR, all of which examined paced respiration compared with control. This meta-analysis supported the prior conclusion that paced respiration as a relaxation technique is not associated with a statistically significant decrease in hot flash frequency or severity. While quality of life was among the outcomes reported to be measured by some of these RCTs, it was measured less often than hot flash frequency or severity, and the results were rarely noted in the SRs.

###### Active comparators

Of the 4 RCTs included in Saensak et al,^45^ 2 compared applied relaxation with acupuncture and were included in a meta-analysis that examined changes in frequency and severity of hot flashes.^98,99^ Of note, follow-up data from these 2 RCTs were combined even though the timing of outcome assessments differed between studies (12 weeks and 24 weeks). In one of these, data from both the superficial needle insertion and electroacupuncture groups were combined into one “acupuncture” group.^99^ There was no significant difference in the change of number of hot flashes per 24 hours between relaxation versus acupuncture (MD 0.05, 95% CI -1.33 to 1.43, I^2^ = 0%, 2 trials). In a sensitivity analysis that excluded individuals who were in the superficial needle insertion group, effects were similar (MD 0.16, 95% CI -1.35 to 1.68, I^2^ = 0%). Similarly, no significant difference was found in severity of hot flashes between groups using the Kupperman index (MD -1.32, 95% CI -5.06 to 2.43, I^2^ = 0%, 2 trials). Saensak et al also included a 3-arm study (n = 11 per arm) evaluating paced respiration, muscle relaxation, and alpha-wave biofeedback (control).^97^ The paced respiration group experienced a significant decrease in frequency of VMS per 24-hour period from the pretest period to the posttest period (p<0.02) while the muscle relaxation group did not. The difference between the groups was not significant.

One new RCT (n = 71)^59^ randomized perimenopausal and postmenopausal women to a traditional 12-week applied relaxation training plus daily home practice compared with a modified version of applied relaxation that had a single in-person training session followed by daily home practice. Authors found similar reductions in hot flash frequency in both groups, though hot flash severity decreased more in the modified applied relaxation training group (p = 0.02).

###### Inactive comparators

Two RCTs^96,97^ included in Saensak et al compared relaxation to inactive controls; however, they were not suitable for meta-analysis due to differences in outcomes reported and large standard deviations in one RCT. Neither found a significant difference in VMS frequency between groups. The SR by Rada et al^48^ provided one additional small RCT comparing deep breathing and guided imagery with no treatment among women with breast cancer (n = 16),^94^ finding no significant differences in the frequency of daily hot flashes (MD 0.50; 95% CI -1.23 to 2.23) or severity (MD 0.64; 95% CI -2.10 to 3.38) between groups. This RCT also found no difference in quality of life between groups.

Two new RCTs also made an inactive comparison.^58,61^ One randomized healthy postmenopausal women (n = 60) to 10 sessions of therapist-led applied relaxation versus a waitlist control condition.^58^ Authors found a significant decrease in hot flash frequency in the applied relaxation group compared with the control group at 12 weeks that was sustained at 3 months (5.0 fewer hot flashes/24 hours compared with 1.9 fewer hot flashes/24 hours respectively [p < 0.001]). A second RCT (n = 46) comparing internet-delivered applied relaxation with control found no differences in hot flash frequency between groups at 10 weeks.^61^ This RCT was limited due to early termination in the setting of more than 60-percent dropout rate. Only 3 (13%) of the women assigned to internet-delivered applied relaxation completed at least 6 of the 9 planned modules.

We combined the findings from one RCT^97^ included in Saensak et al with data from 3 new RCTs comparing paced respiration with control for 2 new meta-analyses.^56,57,60^ For these meta-analyses, we combined control groups for the comparison as follows: attention control groups from 3 trials^56,57,60^ were combined with an alpha-wave feedback control group from a fourth trial,^97^ and 2 attention control comparator groups from one RCT^60^ were combined together. We combined data from end-of-treatment across trials (range 4 to 16 weeks). None of these 4 RCTs included follow-up after completion of the intervention to assess for duration of treatment effects. In each of our 2 meta-analyses, only 3 of the 4 RCTs are included. Freedman et al^97^ measured only hot flash frequency and although Sood et al^60^ measured both frequency and severity, the data on frequency was not sufficient to be included in the meta-analysis. We found that paced respiration was not associated with a statistically significant decrease in hot flash frequency (SMD 0.04, 95% CI -0.73 to 0.82, I^2^ = 56.6%, 3 trials) (Figure 14) or in hot flash severity (SMD 0.06, 95% CI -0.69 to 0.80, I^2^ = 65.1%, 3 trials) (Figure 15), but 95% CIs were wide and do not exclude a small effect.

Figure 14 Forest Plot of Paced Respiration versus Control on Change in Hot Flash Frequency

Figure 15 Forest Plot of Paced Respiration versus Control on Change in Hot Flash Severity at End-of-Treatment

#### Summary of Findings for Meditation, Mindfulness, Hypnosis, and Relaxation

We found that there is some support for the use of hypnosis to treat menopause-associated VMS, but the evidence does not support the use of relaxation techniques to alleviate VMS, and there is insufficient data on the role of mindfulness. To make this determination, we drew from 5 existing SRs (2 good and 3 fair quality)^45-49^ and 6 new RCTs.^56-61^ Overall, the quality of data is poor to mixed. For relaxation, there were 11 trials including 4 from one good-quality SR by Saensak et al,^45^ 1 from a good-quality SR by Rada et al,^48^ and 6 new RCTs.^56-61^ Relaxation techniques studied were mostly applied relaxation and paced respiration. We added to the existing literature by conducting a new meta-analysis of paced respiration trials by combining data from 3 new RCTs and one RCT from the SR.^45^ Similar to conclusions drawn in the SR, our meta-analysis found no significant treatment effect on VMS frequency (SMD 0.04, 95% CI -0.73 to 0.82; n = 162, I^2^ = 56.6%) or severity (SMD 0.06, 95% CI -0.69 to 0.80; n = 211; I^2^ = 65.1%). One small RCT^59^ found that severity of hot flashes decreased more in a modified applied relaxation training group compared with traditional applied relaxation. One fair-quality SR of hypnosis^49^ included 3 RCTs and found a significant decrease in hot flashes compared with no treatment (effect size ranged from 0.479 to 1.25), though no difference when compared to treatment with gabapentin. No new hypnosis trials were found. A fair-quality SR^46^ included the only RCT^95^ of mindfulness-based stress reduction compared with a waitlist control and found no difference in VMS frequency or severity.

### SECONDARY OUTCOMES ACROSS ALL INTERVENTIONS

#### Acupuncture

##### Adverse effects

Four studies included in the SR by Dodin et al^40^ reported mild bruising at the site of acupuncture needle insertion. Four other studies reported no adverse effects associated with acupuncture. Adverse effects, if any, reported in the other 7 RCTs were not discussed by Dodin et al. Adverse effects were not reported in the RCT by Avis et al.^52^ No significant adverse events were reported in the RCT by Ee et al,^50^ but among the 327 patients allocated to either true or sham acupuncture, 8 (2%) reported bleeding or bruising, 7 (2%) reported pain, 3 (1%) reported syncope or presyncope, 3 (1%) reported worsening of symptoms, 1 reported tingling near an acupuncture point, 1 reported swelling around an acupuncture point and itching of the whole arm, 1 reported skin sensitivity and feeling hot, 1 reported nervousness, and 1 reported essential tremor. The RCT by Mao et al^51^ reported 5 (17%) adverse effects in the real acupuncture arm, 1 (3%) in the sham arm, 8 (27%) in the placebo pill group, and 13 (43%) in the gabapentin arm (p value across the 4 groups was 0.005). All of the adverse effects were graded as mild.

##### Other secondary outcomes

Secondary outcomes such as sleep quality/quantity and symptoms of depression or anxiety were evaluated in some of the RCTs included in the SR by Dodin et al,^40^ but the findings were not reported. Of the 3 new RCTs, the one by Avis et al^52^ had the most extensive reporting of secondary outcomes. At the 6-month end-of-treatment assessment period in this trial of 209 perimenopausal or postmenopausal women, acupuncture was associated with significant improvement of sleep, when compared with a waitlist control, using the Pittsburgh Sleep Quality Index score, the sleep domain of the Women's Health Questionnaire, and the Patient-Reported Outcomes Measurement Information System (PROMIS) Sleep Disturbance short form. No between-group differences were found at 6 months by the different study instruments designed to assess depressive or anxiety symptoms.

#### Yoga

##### Adverse effects

Of the 5 RCTs in the SR by Cramer et al^43^ plus the 2 new RCTs, only one reported assessing adverse events that are possibly associated with yoga, and found none.^87^

##### Other secondary outcomes

The SR^43^ found positive long- and-short term effects of yoga on psychological symptoms, but no effect of yoga on sleep symptoms. Among the 2 new RCTs, one^55^ found positive effects of yoga on psychological symptoms, but did not examine sleep outcomes. The other^54^ was not sufficiently powered to detect differences and thus findings were inconsistent. However, participants in the yoga intervention did not experience meaningful changes in sleep quality, perceived stress, or depression.

#### Structured Exercise

##### Adverse effects

No serious adverse events were reported in the 5 RCTs included in the SR by Daley et al^44^ for any of the outcomes. In one RCT, the proportion of incident adverse events were similar across the exercise group (17%) and the usual activity group (18%).^91^

##### Other secondary outcomes

One new RCT^62^ measured menopause-specific quality of life using subscales from the Women's Health Questionnaire. That study found significantly lower sleep problem scores (mean difference -0.11, 95% CI -0.21 to -0.01) among the exercise group when compared with control at the 6-month follow up. No statistically significant effects were found for anxiety (mean difference -1, 95% CI -2.0 to 0.02) at the 12-month follow-up.

One new RCT^63^ measured generic quality of life using the SF-36 Short Form Health Survey. Moderate effect sizes were found for short (effect size 0.46, p<0.001) and long-term follow-up (effect size 0.41, p = 0.002) among the exercise group compared with control for physical function.

Four years after the intervention, Luoto et al^90^ published a companion paper using the original cohort^103^ examining long-term quality of life measured by the SF-36 Health Survey Questionnaire. In the companion study, the exercise group had a significantly higher physical functioning (OR 1.41, 95% CI 1.00 to 1.99) compared with the control group. No significant associations were found for higher good role functioning (OR 1.21, 95% CI 0.88 to 1.67), physical health (OR 1.33, 95% CI 0.96 to 1.84), or general health (OR 1.14, 95% CI 0.81 to 1.62).^103^

An additional companion publication to Luoto et al^90^ focused on sleep quality.^104^ Outcomes for this study were sleep quality and the amount of hot flashes during sleep measured by mobile phone with a 1 (poor) to 5 (good) scale response to each question. Sleep quality was significantly improved in the exercise intervention group compared with the control (OR 1.02, 95% CI 1.0 to 1.05, p = 0.043).^104^ The amount of hot flashes related to sleep diminished (p = 0.004) by the end of the intervention.

#### Meditation, Mindfulness, Hypnosis, and Relaxation

##### Adverse effects

Overall, adverse effects were rarely reported and when noted were mild. For interventions of hypnosis, the SR by Cramer et al^49^ found 3 adverse events in the gabapentin control group in one included RCT,^102^ and no dropouts due to adverse events or no adverse events related to the intervention in 2 other RCTs.^100,101^ One new RCT of paced breathing compared with control^60^ noted that more women in the paced breathing arm reported mild dizziness than in the control arm.

##### Other secondary outcomes

In general, secondary outcomes of interest were rarely reported in the SRs addressing relaxation, hypnosis, or mindfulness, and the results were mixed when they were reported. In our examination of reported secondary outcomes in the SRs and new RCTs, the findings were generally not significant, with a few exceptions. In one RCT included by Cramer et al,^101^ hypnosis decreased depression and anxiety compared with no treatment, though no specific results were given. In the one RCT of mindfulness included in the SR by Woods et al,^46^ mindfulness-based stress reduction significantly improved both anxiety and sleep quality at 9 weeks compared with a waitlist control group (p<0.01).