# REFERENCES

1 Woods NF, Mitchell ES. Symptoms during the perimenopause: prevalence, severity, trajectory, and significance in women's lives. Am J Med. 2005;118 Suppl 12B:14-24.16414323
2 Santoro N. Perimenopause: From Research to Practice. J Womens Health (Larchmt). 2015.
3 Avis NE, Crawford SL, Greendale G, . Duration of menopausal vasomotor symptoms over the menopause transition. JAMA Intern Med. 2015;175(4):531-539.25686030
4 Thurston RC, Sowers MR, Sternfeld B, . Gains in body fat and vasomotor symptom reporting over the menopausal transition: the study of women's health across the nation. Am J Epidemiol. 2009;170(6):766-774.19675142
5 Guthrie JR, Dennerstein L, Taffe JR, Donnelly V. Health care-seeking for menopausal problems. Climacteric. 2003;6(2):112-117.12841881
6 Avis NE, Colvin A, Bromberger JT, . Change in health-related quality of life over the menopausal transition in a multiethnic cohort of middle-aged women: Study of Women's Health Across the Nation. Menopause. 2009;16(5):860-869.19436224
7 Ayers B, Hunter MS. Health-related quality of life of women with menopausal hot flushes and night sweats. Climacteric. 2013;16(2):235-239.22809134
8 Bhattacharya SM, Jha A. A comparison of health-related quality of life (HRQOL) after natural and surgical menopause. Maturitas. 2010;66(4):431-434.20434859
9 Thurston RC, Bromberger JT, Joffe H, . Beyond frequency: who is most bothered by vasomotor symptoms? Menopause. 2008;15(5):841-847.18521049
10 North American Menopause Society. 2012 hormone therapy position statement. Menopause. 2012;19(3):257-271.22367731
11 Menopause: diagnosis and management. Vol NICE Guidelines [NG23]. November 2015. Available at: https://www.nice.org.uk/guidance/ng23. Accessed January 25, 2016.
12 The North American Menopause Society Statement on Continuing Use of Systemic Hormone Therapy After Age 65. Menopause. 2015;22(7):693.26035150
13 U.S. Food and Drug Administration. Guidance for Industry: Estrogen and Estrogen/Progestin Drug Products to Treat Vasomotor Symptoms and Vulvar and Vaginal Atrophy Symptoms—Recommendations for Clinical Evaluation. (Draft guidance from the Center for Drug Evaluation and Research (CDER), January 2003). Available at: http://www.fda.gov/downloads/Drugs/DrugSafety/InformationbyDrugClass/UCM135338.pdf. Accessed January 27, 2016.
14 ACOG Practice Bulletin No. 141: management of menopausal symptoms. Obstet Gynecol. 2014;123(1):202-216.24463691
15 Stuenkel CA, Davis SR, Gompel A, . Treatment of Symptoms of the Menopause: An Endocrine Society Clinical Practice Guideline. J Clin Endocrinol Metab. 2015;100(11):3975-4011.26444994
16 Das SR, Kinsinger LS, Yancy WS, Jr., . Obesity prevalence among veterans at Veterans Affairs medical facilities. Am J Prev Med. 2005;28(3):291-294.15766618
17 Farmer MM, Rose DE, Riopelle D, Lanto AB, Yano EM. Gender differences in smoking and smoking cessation treatment: an examination of the organizational features related to care. Womens Health Issues. 2011;21(4 Suppl):S182-189.21724139
18 Lehavot K, Hoerster KD, Nelson KM, Jakupcak M, Simpson TL. Health indicators for military, veteran, and civilian women. Am J Prev Med. 2012;42(5):473-480.22516487
19 Gerber MR, King MW, Pineles SL, . Hormone therapy use in women veterans accessing veterans health administration care: a national cross-sectional study. J Gen Intern Med. 2015;30(2):169-175.25373833
20 Taylor M. Complementary and Alternative Approaches to Menopause. Endocrinol Metab Clin North Am. 2015;44(3):619-648.26316247
21 Gartoulla P, Davis SR, Worsley R, Bell RJ. Use of complementary and alternative medicines for menopausal symptoms in Australian women aged 40-65 years. Med J Aust. 2015;203(3):146, 146e.141-146.
22 Gentry-Maharaj A, Karpinskyj C, Glazer C, . Use and perceived efficacy of complementary and alternative medicines after discontinuation of hormone therapy: a nested United Kingdom Collaborative Trial of Ovarian Cancer Screening cohort study. Menopause. 2015;22(4):384-390.25290539
23 National Center for Complementary and Integrative Health. Complementary, Alternative, or Integrative Health: What's In a Name? Available at: https://nccih.nih.gov/health/integrative-health. Accessed March 10, 2016.
24 Grant MD, Marbella A, Wang AT, . Menopausal Symptoms: Comparative Effectiveness of Therapies. Comparative Effectiveness Review No. 147. (Prepared by Blue Cross and Blue Shield Association Technology Evaluation Center Evidence-based Practice Center under Contract No. 290-2007-10058-I.) AHRQ Publication No. 15-EHC005-EF. Rockville, MD: Agency for Healthcare Research and Quality; March 2015. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
25 The North American Menopause Society. Nonhormonal management of menopause-associated vasomotor symptoms: 2015 position statement of The North American Menopause Society. Menopause. 2015;22(11):1155-1174.26382310
26 Becker LA, Oxman AD. Chapter 22: Overviews of reviews. In: Higgins JPT, Green S (editors). Cochrane Handbook for Systematic Reviews of Interventions. Version 5.1.0 [updated March 2011]. The Cochrane Collaboration, 2011. Available at: www.cochrane-handbook.org. Accessed October 21, 2015.
27 Agency for Healthcare Research and Quality. Methods Guide for Effectiveness and Comparative Effectiveness Reviews: Rockville, MD: Agency for Healthcare Research and Quality. Available at: http://www.effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?pageaction = displayproduct&productid = 318 (https://effectivehealthcare.ahrq.gov/topics/cer-methods-guide/overview/). Accessed July 16, 2015.
28 Goldstein KM, McDuffie JR, Shepherd-Banigan M, . Nonpharmacologic, nonherbal management of menopause-associated vasomotor symptoms: an umbrella systematic review (protocol). Syst Rev. 2016;5(1):56.27056180
29 PROSPERO: International prospective register of systematic reviews. #CRD42016029335: Available at: http://www.crd.york.ac.uk/prospero/. Accessed January 25, 2016.
30 Whiting P, Savovic J, Higgins JP, . ROBIS: A new tool to assess risk of bias in systematic reviews was developed. J Clin Epidemiol. 2015.
31 Guyatt G, Oxman AD, Akl EA, . GRADE guidelines: 1. Introduction-GRADE evidence profiles and summary of findings tables. J Clin Epidemiol. 2011;64(4):383-394.21195583
32 Balshem H, Helfand M, Schunemann HJ, . GRADE guidelines: 3. Rating the quality of evidence. J Clin Epidemiol. 2011;64(4):401-406.21208779
33 Higgins JPT, Altman DG, Gøtzsche PC, . The Cochrane Collaboration's tool for assessing risk of bias in randomised trials. BMJ. 2011;343.
34 Robinson KA, Chou R, Berkman ND, . Twelve recommendations for integrating existing systematic reviews into new reviews: EPC guidance. J Clin Epidemiol. 2015.
35 Engauge Digitizer (software package). Available at: http://markummitchell.github.io/engauge-digitizer/. Accessed February 1, 2016.
36 Viechtbauer W. Conducting Meta-Analyses in R with the metafor Package (2010). Available at: https://www.jstatsoft.org/article/view/v036i03. Accessed April 6, 2016.
37 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. 1986;7(3):177-188.3802833
38 Knapp G, Hartung J. Improved tests for a random effects meta-regression with a single covariate. Stat Med. 2003;22(17):2693-2710.12939780
39 Cohen J. Statistical power analysis for the behavioral sciences. 2nd ed. Hillsdale, N.J.: L. Erlbaum Associates; 1988.
40 Dodin S, Blanchet C, Marc I, . Acupuncture for menopausal hot flushes. Cochrane Database Syst Rev 2013;7:CD007410.
41 Garcia MK, Graham-Getty L, Haddad R, . Systematic review of acupuncture to control hot flashes in cancer patients. Cancer. 2015;121(22):3948-3958.26281028
42 Garcia MK, McQuade J, Lee R, Haddad R, Spano M, Cohen L. Acupuncture for symptom management in cancer care: an update. Curr Oncol Rep. 2014;16(12):418.25325937
43 Cramer H, Lauche R, Langhorst J, Dobos G. Effectiveness of yoga for menopausal symptoms: a systematic review and meta-analysis of randomized controlled trials. Evid Based Complement Alternat Med. 2012;2012:863905.23304220
44 Daley A, Stokes-Lampard H, Thomas A, MacArthur C. Exercise for vasomotor menopausal symptoms. Cochrane Database Syst Rev. 2014;11:Cd006108.
45 Saensak S, Vutyavanich T, Somboonporn W, Srisurapanont M. Relaxation for perimenopausal and postmenopausal symptoms. Cochrane Database Syst Rev 2014;7:CD008582.
46 Woods NF, Mitchell ES, Schnall JG, . Effects of mind-body therapies on symptom clusters during the menopausal transition. Climacteric. 2014;17(1):10-22.23937432
47 Innes KE, Selfe TK, Vishnu A. Mind-body therapies for menopausal symptoms: a systematic review. Maturitas. 2010;66(2):135-149.20167444
48 Rada G, Capurro D, Pantoja T, . Non-hormonal interventions for hot flushes in women with a history of breast cancer. Cochrane Database Syst Rev. 2010(9):Cd004923.
49 Cramer H, Lauche R, Paul A, Langhorst J, Kummel S, Dobos GJ. Hypnosis in breast cancer care: a systematic review of randomized controlled trials. Integr Cancer Ther. 2015;14(1):5-15.25233905
50 Ee C, Xue C, Chondros P, . Acupuncture for Menopausal Hot Flashes: A Randomized Trial. Ann Intern Med. 2016;164(3):146-154.26784863
51 Mao JJ, Bowman MA, Xie SX, Bruner D, DeMichele A, Farrar JT. Electroacupuncture Versus Gabapentin for Hot Flashes Among Breast Cancer Survivors: A Randomized Placebo-Controlled Trial. J Clin Oncol. 2015;33(31):3615-3620.26304905
52 Avis NE, Coeytaux RR, Isom S, Prevette K, Morgan T. Acupuncture in Menopause (AIM) study: a pragmatic, randomized controlled trial. Menopause. 2016.
53 Nedeljkovic M, Tian L, Ji P, . Effects of acupuncture and Chinese herbal medicine (Zhi Mu 14) on hot flushes and quality of life in postmenopausal women: results of a four-arm randomized controlled pilot trial. Menopause. 2014;21(1):15-24.23676632
54 Avis NE, Legault C, Russell G, Weaver K, Danhauer SC. Pilot study of integral yoga for menopausal hot flashes. Menopause. 2014;21(8):846-854.24473534
55 Ngowsiri K, Tanmahasamut P, Sukonthasab S. Rusie Dutton traditional Thai exercise promotes health related physical fitness and quality of life in menopausal women. Complement Ther Clin Pract. 2014;20(3):164-171.25066942
56 Carpenter JS, Burns DS, Wu J, . Paced respiration for vasomotor and other menopausal symptoms: a randomized, controlled trial. J Gen Intern Med. 2013;28(2):193-200.22936289
57 Huang AJ, Phillips S, Schembri M, Vittinghoff E, Grady D. Device-guided slow-paced respiration for menopausal hot flushes: a randomized controlled trial. Obstet Gynecol. 2015;125(5):1130-1138.25932840
58 Lindh-Astrand L, Nedstrand E. Effects of applied relaxation on vasomotor symptoms in postmenopausal women: a randomized controlled trial. Menopause. 2013;20(4):401-408.23149867
59 Saensak S, Vutyavanich T, Somboonporn W, Srisurapanont M. Effectiveness of a modified version of the applied relaxation technique in treatment of perimenopausal and postmenopausal symptoms. Int J Womens Health. 2013;5:765-771.24235848
60 Sood R, Sood A, Wolf SL, . Paced breathing compared with usual breathing for hot flashes. Menopause. 2013;20(2):179-184.22990758
61 Lindh-Astrand L, Holm ACS, Sydsjö G, Andersson G, Carlbring P, Nedstrand E. Internet-delivered applied relaxation for vasomotor symptoms in postmenopausal women: Lessons from a failed trial. Maturitas. 2015;80(4):432-434.25700856
62 Daley AJ, Thomas A, Roalfe AK, . The effectiveness of exercise as treatment for vasomotor menopausal symptoms: randomised controlled trial. BJOG. 2015;122(4):565-575.25516405
63 Duijts SF, van Beurden M, Oldenburg HS, . Efficacy of cognitive behavioral therapy and physical exercise in alleviating treatment-induced menopausal symptoms in patients with breast cancer: results of a randomized, controlled, multicenter trial. J Clin Oncol. 2012;30(33):4124-4133.23045575
64 Garcia MK, McQuade J, Haddad R, . Systematic review of acupuncture in cancer care: a synthesis of the evidence. J Clin Oncol. 2013;31(7):952-960.23341529
65 Walker EM, Rodriguez AI, Kohn B, . Acupuncture versus venlafaxine for the management of vasomotor symptoms in patients with hormone receptor-positive breast cancer: a randomized controlled trial. J Clin Oncol. 2010;28(4):634-640.20038728
66 Liljegren A, Gunnarsson P, Landgren BM, Robeus N, Johansson H, Rotstein S. Reducing vasomotor symptoms with acupuncture in breast cancer patients treated with adjuvant tamoxifen: a randomized controlled trial. Breast Cancer Res Treat. 2012;135(3):791-798.21153699
67 Bao T, Cai L, Snyder C, . Patient-reported outcomes in women with breast cancer enrolled in a dual-center, double-blind, randomized controlled trial assessing the effect of acupuncture in reducing aromatase inhibitor-induced musculoskeletal symptoms. Cancer. 2014;120(3):381-389.24375332
68 Vincent A, Barton DL, Mandrekar JN, . Acupuncture for hot flashes: a randomized, sham-controlled clinical study. Menopause. 2007;14(1):45-52.17019380
69 Venzke L, Calvert JF, Jr., Gilbertson B. A randomized trial of acupuncture for vasomotor symptoms in post-menopausal women. Complement Ther Med. 2010;18(2):59-66.20430288
70 Park JE, Lee MS, Jung S, . Moxibustion for treating menopausal hot flashes: a randomized clinical trial. Menopause. 2009;16(4):660-665.19293729
71 Painovich JM, Shufelt CL, Azziz R, . A pilot randomized, single-blind, placebo-controlled trial of traditional acupuncture for vasomotor symptoms and mechanistic pathways of menopause. Menopause. 2012;19(1):54-61.21968279
72 Nir Y, Huang MI, Schnyer R, Chen B, Manber R. Acupuncture for postmenopausal hot flashes. Maturitas. 2007;56(4):383-395.17182200
73 Nedstrand E, Wyon Y, Hammar M, Wijma K. Psychological well-being improves in women with breast cancer after treatment with applied relaxation or electro-acupuncture for vasomotor symptom. J Psychosom Obstet Gynaecol. 2006;27(4):193-199.17225620
74 Kim DI, Jeong JC, Kim KH, . Acupuncture for hot flushes in perimenopausal and postmenopausal women: a randomised, sham-controlled trial. Acupunct Med. 2011;29(4):249-256.21653660
75 Kim KH, Kang KW, Kim DI, . Effects of acupuncture on hot flashes in perimenopausal and postmenopausal women--a multicenter randomized clinical trial. Menopause. 2010;17(2):269-280.19907348
76 Hervik J, Mjaland O. Acupuncture for the treatment of hot flashes in breast cancer patients, a randomized, controlled trial. Breast Cancer Res Treat. 2009;116(2):311-316.18839306
77 Deng G, Vickers A, Yeung S, . Randomized, controlled trial of acupuncture for the treatment of hot flashes in breast cancer patients. J Clin Oncol. 2007;25(35):5584-5590.18065731
78 Borud EK, Alraek T, White A, . The Acupuncture on Hot Flushes Among Menopausal Women (ACUFLASH) study, a randomized controlled trial. Menopause. 2009;16(3):484-493.19423996
79 Bokmand S, Flyger H. Acupuncture relieves menopausal discomfort in breast cancer patients: a prospective, double blinded, randomized study. Breast. 2013;22(3):320-323.22906948
80 Avis NE, Legault C, Coeytaux RR, . A randomized, controlled pilot study of acupuncture treatment for menopausal hot flashes. Menopause. 2008;15(6):1070-1078.18528313
81 Zhou J, Qu F, Sang X, Wang X, Nan R. Acupuncture and auricular acupressure in relieving menopausal hot flashes of bilaterally ovariectomized chinese women: a randomized controlled trial. Evid Based Complement Alternat Med. 2011;2011:713274.19189989
82 Frisk J, Carlhall S, Kallstrom AC, Lindh-Astrand L, Malmstrom A, Hammar M. Long-term follow-up of acupuncture and hormone therapy on hot flushes in women with breast cancer: a prospective, randomized, controlled multicenter trial. Climacteric. 2008;11(2):166-174.18365859
83 Wyon Y, Wijma K, Nedstrand E, Hammar M. A comparison of acupuncture and oral estradiol treatment of vasomotor symptoms in postmenopausal women. Climacteric. 2004;7(2):153-164.15497904
84 Cornell JE, Mulrow CD, Localio R, . Random-effects meta-analysis of inconsistent effects: a time for change. Ann Intern Med. 2014;160(4):267-270.24727843
85 Elavsky S, McAuley E. Physical activity and mental health outcomes during menopause: a randomized controlled trial. Ann Behav Med. 2007;33(2):132-142.17447865
86 Joshi S, Khandwe R, Bapat D, Deshmukh U. Effect of yoga on menopausal symptoms. Menopause Int. 2011;17(3):78-81.21903710
87 Afonso RF, Hachul H, Kozasa EH, . Yoga decreases insomnia in postmenopausal women: a randomized clinical trial. Menopause. 2012;19(2):186-193.22048261
88 Carson JW, Carson KM, Porter LS, Keefe FJ, Seewaldt VL. Yoga of Awareness program for menopausal symptoms in breast cancer survivors: results from a randomized trial. Support Care Cancer. 2009;17(10):1301-1309.19214594
89 Chattha R, Raghuram N, Venkatram P, Hongasandra NR. Treating the climacteric symptoms in Indian women with an integrated approach to yoga therapy: a randomized control study. Menopause. 2008;15(5):862-870.18463543
90 Luoto R, Moilanen J, Heinonen R, . Effect of aerobic training on hot flushes and quality of life--a randomized controlled trial. Ann Med. 2012;44(6):616-626.21639722
91 Sternfeld B, Guthrie KA, Ensrud KE, . Efficacy of exercise for menopausal symptoms: a randomized controlled trial. Menopause. 2014;21(4):330-338.23899828
92 Lindh-Astrand L, Nedstrand E, Wyon Y, Hammar M. Vasomotor symptoms and quality of life in previously sedentary postmenopausal women randomised to physical activity or estrogen therapy. Maturitas. 2004;48(2):97-105.15172083
93 Hanachi P, Golkho S. Assessment of soy phytoestrogens and exercise on lipid profiles and menopause symptoms in menopausal women. Journal of Biological Sciences. 2008;8(4):789-793.
94 Fenlon D. Relaxation therapy as an intervention for hot flushes in women with breast cancer. Eur J Oncol Nurs. 1999;3(4):223-231.
95 Carmody J, Crawford S, Churchill L. A pilot study of mindfulness-based stress reduction for hot flashes. Menopause. 2006;13(5):760-769.16932242
96 Fenlon DR, Corner JL, Haviland JS. A randomized controlled trial of relaxation training to reduce hot flashes in women with primary breast cancer. J Pain Symptom Manage. 2008;35(4):397-405.18359433
97 Freedman RR, Woodward S. Behavioral treatment of menopausal hot flushes: evaluation by ambulatory monitoring. Am J Obstet Gynecol. 1992;167(2):436-439.1497048
98 Nedstrand E, Wijma K, Wyon Y, Hammar M. Vasomotor symptoms decrease in women with breast cancer randomized to treatment with applied relaxation or electro-acupuncture: a preliminary study. Climacteric. 2005;8(3):243-250.16390756
99 Zaborowska E, Brynhildsen J, Damberg S, . Effects of acupuncture, applied relaxation, estrogens and placebo on hot flushes in postmenopausal women: an analysis of two prospective, parallel, randomized studies. Climacteric. 2007;10(1):38-45.
100 Elkins GR, Fisher WI, Johnson AK, Carpenter JS, Keith TZ. Clinical hypnosis in the treatment of postmenopausal hot flashes: a randomized controlled trial. Menopause. 2013;20(3):291-298.23435026
101 Elkins G, Marcus J, Stearns V, . Randomized trial of a hypnosis intervention for treatment of hot flashes among breast cancer survivors. J Clin Oncol. 2008;26(31):5022-5026.18809612
102 Maclaughlan David S, Salzillo S, Bowe P, . Randomised controlled trial comparing hypnotherapy versus gabapentin for the treatment of hot flashes in breast cancer survivors: a pilot study. BMJ Open. 2013;3(9):e003138.
103 Mansikkamaki K, Raitanen J, Nygard CH, Tomas E, Rutanen R, Luoto R. Long-term effect of physical activity on health-related quality of life among menopausal women: a 4-year follow-up study to a randomised controlled trial. BMJ Open. 2015;5(9):e008232.
104 Mansikkamaki K, Raitanen J, Nygard CH, . Sleep quality and aerobic training among menopausal women--a randomized controlled trial. Maturitas. 2012;72(4):339-345.22673453
105 Kinser PA, Robins JL. Control group design: enhancing rigor in research of mind-body therapies for depression. Evid Based Complement Alternat Med. 2013;2013:140467.23662111
106 McCambridge J, Sorhaindo A, Quirk A, Nanchahal K. Patient preferences and performance bias in a weight loss trial with a usual care arm. Patient Educ Couns. 2014;95(2):243-247.24492159
107 Chiu HY, Pan CH, Shyu YK, Han BC, Tsai PS. Effects of acupuncture on menopause-related symptoms and quality of life in women in natural menopause: a meta-analysis of randomized controlled trials. Menopause. 2015;22(2):234-244.25003620
108 Lund I, Lundeberg T. Are minimal, superficial or sham acupuncture procedures acceptable as inert placebo controls? Acupunct Med. 2006;24(1):13-15.16618044
109 Lesi G, Razzini G, Musti MA, . Acupuncture as an integrative approach for the treatment of hot flashes in women with breast cancer: a prospective multicenter randomized controlled trial (AcCliMaT). J Clin Oncol. 2016;34(15):1795-1802.27022113
110 Carpenter JS, Woods NF, Otte JL, . MsFLASH participants' priorities for alleviating menopausal symptoms. Climacteric. 2015:1-8.