# METHODS

Given the multiple high-quality SRs in this topic area, we chose a method commonly known as an umbrella review, or review of reviews. We supplemented this approach by also evaluating randomized controlled trials (RCTs) published after the most recent good-quality SR for each of the eligible interventions. We followed methodological guidance from the Cochrane Collaboration^26^ and AHRQ's Evidence-based Practice Centers.^27^

## TOPIC DEVELOPMENT

Numerous interventions could be considered nonpharmacologic treatments for VMS in perimenopausal and postmenopausal women, particularly variations of complementary and alternative medicine approaches to symptom control.^20^ To focus the selection of interventions for this review, we invited individuals with expertise in the field of menopause management both from within the Veterans Health Administration (VHA) and outside the VHA to participate in a technical expert panel. This panel provided consultation during the process of reviewing and organizing a list of potential interventions originally generated by the primary review team based on published literature and clinical practice. Table 1 lists the eligible nonpharmacologic interventions and definitions for this umbrella review.

Table 1 Eligible Interventions and Definitions

Intervention category | Definitions and examples
Acupuncture, acupressure | Acupuncture from any tradition was considered, including auricular acupuncture, electroacupuncture, acupressure, and laser acupuncture. Excluded were studies where acupuncture was administered in conjunction with Chinese herbal therapies. Cupping therapy was excluded unless it was a component of an acupuncture intervention.
Yoga, tai chi, qigong (as defined by study investigators) | Yoga typically involves combinations of physical exercises and bodily positions or postures, breath control practices, and meditation.
Yoga, tai chi, qigong (as defined by study investigators) | Tai chi typically involves a series of movements performed in a slow, focused manner accompanied by deep breathing.
Yoga, tai chi, qigong (as defined by study investigators) | Qigong typically involves a combination of coordinated body postures and movement, breathing, and meditation.
Structured exercise, physical activity | Structured exercise is defined as regular physical activity done with the intention of improving or maintaining physical fitness or health, or performed as part of a class or with support from a health professional.
Meditation, mindfulness, relaxation | Practices include:; - Alexander technique; - Benson's relaxation response; - Bernstein and Borkovec's progressive relaxation; - Everly and Rosenfeld's passive relaxation; - Guided imagery-based approaches; - Hypnosis; - Madder's release; - Mindfulness-based stress reduction; - Mitchell method; - Osts's applied relaxation; - Paced respiration; - Poppen's behavioral relaxation training; - Progressive relaxation; - Roll breathing; - 4-7-8 breath technique; - Other approaches that focus on diaphragmatic breathing

The final key question (KQ), developed in consultation with stakeholders, was:

In women with vasomotor symptoms (VMS) that are associated with perimenopause or postmenopause, what are the effects on VMS, health-related quality of life, and adverse events of the following nonpharmacologic, nonhormonal interventions?

- Acupuncture
- Yoga, tai chi, and qigong
- Structured exercise
- Meditation, mindfulness, hypnosis, and relaxation

We followed a standard protocol for this review,^28^ and each step was pilot-tested to train and calibrate study investigators. The PROSPERO registration number is CRD42016029335.^29^

## SEARCH STRATEGY

In consultation with an expert librarian, we conducted searches of MEDLINE (via PubMed) and the Cochrane Database of Systematic Reviews from January 2010 through November 2015 for SRs, as well as searches of PubMed, EMBASE, CINAHL, and the Allied and Complementary Medicine Database from January 2012 through February 2016 for RCTs. We used MeSH keywords and selected free-text terms for the interventions and health conditions of interest as well as terms for SRs and RCTs. The exact search strategies used are in Appendix A. All eligible SRs along with relevant umbrella and narrative reviews identified during citation screening were reviewed for additional relevant RCTs. All citations were imported into 2 electronic databases (for referencing, EndNote^®^ Version X7, Thomson Reuters, Philadelphia, PA; for data abstraction, DistillerSR; Evidence Partners Inc., Manotick, ON, Canada).

## STUDY SELECTION

Using prespecified inclusion/exclusion criteria (Table 2), titles and abstracts of SRs and RCTs identified through our primary search were reviewed by 2 reviewers for potential relevance to the key question. Articles included by either reviewer underwent full-text screening. At the full-text screening stage, 2 independent reviewers were required to agree on a final inclusion/exclusion decision. Disagreements were resolved by discussion or by a third investigator. Articles meeting eligibility criteria were included for data abstraction.

Table 2 Inclusion and Exclusion Criteria

Study Characteristic | Inclusion/Exclusion Criteria
Population | Perimenopausal and postmenopausal women who are experiencing bothersome VMS. Perimenopause is defined as amenorrhea for > 60 days in the past 12 months; postmenopause is defined as being without a menstrual cycle due to spontaneous or surgical reasons for the preceding 12 months. Bothersome VMS is defined as any of the following:; - Self-identified “bothersome” hot flashes; - Moderate to severe VMS as defined by the FDA^13^; - Hot flashes that occur at least 6 days in the previous 2 weeks^3^; - Hot flashes associated with functional impairment (eg, impairment in role, social, emotional, or physical functioning)
Interventions^a^ | - Acupuncture, acupressure; - Yoga, tai chi, qigong (as defined by study investigators); - Structured exercise, physical activity; - Meditation, mindfulness, hypnosis, relaxation
Comparators | Any inactive control (waitlist, attention, sham acupuncture, information control, or unenhanced usual care) or active comparator (including hormone treatments, antidepressants or other pharmacotherapies, dietary supplements, health education, and alternative forms of exercise)
Outcomes | Primary:; - Frequency and severity of VMS; - Overall and condition-specific health-related quality of life; Secondary:; - Psychological well-being (ie, depressive or anxiety symptoms) and sleep quality, prioritizing validated scales over unvalidated scales or single-symptom measures; - Serious adverse effects and adverse effects
Timing | - For SRs, timing of outcome assessments as specified by the review; - For RCTs, outcomes assessed at > 60 days after treatment assignment
Setting | Outpatient or community settings (and mixed settings inclusive of outpatient/community settings)
Study design | Included: SRs and RCTs that evaluate an eligible intervention for VMS that is associated with perimenopause or postmenopause Excluded: SRs of complementary and alternative therapies in general without a specific focus on the interventions of interest, and umbrella reviews
Publication type | Included: Full articles published in peer-reviewed journals from January 2010 to November 2015 for SRs, or from January 2012 to February 2016 for RCTs Excluded: Abstracts and dissertations

a Intervention definitions are in Table 1.

Abbreviations: RCT = randomized controlled trial; SR = systematic review; VMS = vasomotor symptoms

## DATA ABSTRACTION

Data from published fair- or good-quality SRs and newly identified RCTs were abstracted into a customized DistillerSR database by one reviewer and overread by a second reviewer. Disagreements were resolved by discussion or by a third investigator. Data elements include descriptors to characterize the type of study, study population, intervention, comparator, outcomes reported, study quality, and author conclusions.

## QUALITY ASSESSMENT

Two reviewers assessed the quality of SRs and RCTs (Appendix B). Disagreements were resolved by discussion or by a third investigator. For SRs, we used the following key quality criteria, adapted from ROBIS^30^ and AMSTAR^7^: search methods adequate for replication and comprehensive; selection bias avoided; data abstracted reliably; characteristics of primary literature reported and quality assessed appropriately; results synthesized using appropriate methods; publication bias assessed; conflict of interest reported; and conclusions supported by results. Based on these criteria, SRs were categorized as good, fair, or poor quality. Good- and fair-quality SRs should provide sufficient information to assess the strength of the body of evidence using the GRADE criteria.^31,32^ Poor-quality reviews were excluded from our review.

For newly identified RCTs, we used the Cochrane Collaboration's risk of bias (ROB) tool,^33^ which categorizes biases by 6 domains (selection bias, performance bias, detection bias, attrition bias, reporting bias, and other bias) and makes a summary assessment. For each item, a summary rating (high, low, or unclear ROB) was made (Appendix C).

## DATA SYNTHESIS

We grouped the SRs and RCTs by intervention. We prioritized SRs that are the highest quality and most relevant to the study question.^34^ Relevance was assessed using the PICOTS (population, intervention, comparator, outcome, timing, setting) framework along with the search date, review methods, and completeness of reporting. For each intervention, tables or graphical displays describe the studies included, study quality, and treatment effects. We report intervention effects separately for inactive and active comparators. We examined SRs for relevant subgroup analyses, including concurrent use of hormone therapy, effects in women with and without breast cancer, perimenopausal and postmenopausal women, and women with surgical versus natural menopause.

Although umbrella reviews typically do not search for new primary studies, our review incorporated this step in order to identify important new data. As a framework for determining whether a new quantitative synthesis is needed, we considered the number of new studies, the sample size, and the strength of evidence (SOE) domains.^31^ When an updated or new meta-analysis was indicated and feasible, we computed summary estimates of effect for each intervention using end-of-treatment outcomes. When means and measures of dispersion were not reported in the text, they were approximated from figures with the use of Engauge Digitizer.^35^ We imputed missing control group standard deviations (SDs) in one study (and for 2 outcome measures) by using the maximum of all available SDs from other arms in the same study, which were measured on the same scale.

One difficulty in performing new meta-analyses for the quality of life outcome was the large variation in the types of scales used to measure this variable. For example, a scale could have separate subscales labeled VMS, physical, and somatic, all of which we considered part of physical domain but not address the social, occupational or functional aspects, whereas other scales contained occupational, social, and emotional subscales, but did not address the physical domain.

We devised a working definition for health-related quality of life in order to bring some degree of homogeneity to our analyses. To be included, a scale must have had at least 2 of the following 5 domains that were determined to be major: emotional, functional, occupational, physical, and/or social. These 5 domains were found in 50% or more of all the scales represented in the studies that examined quality of life. Of the eight scales used in the studies included in our meta-analyses, only one scale, the MENQOL, contained only 2 of the 5 domains and only one scale, the SF-36, contained all 5 domains. All others contained at least 3 of the 5 major domains used in our working definition.

We used R version 3.1.2 (R Foundation for Statistical Computing, Vienna, Austria) with the metafor package^36^ to calculate random-effects model summary estimates of effect with Knapp and Hartung adjustment of standard errors of the estimated coefficients.^37,38^ Because outcomes were measured across the trials using different instruments, outcome measures were combined using standardized mean differences (SMDs) in a random-effects model. The SMD was calculated by dividing the difference in mean values by the pooled SDs of the 2 groups. SMDs of 0.2 can be considered small treatment effects; 0.5, moderate effects; and ≥0.8, large effects.^39^ For hot flash frequency, we transformed the pooled SMD^26^ into hot flashes/day by multiplying the SMD by the standard deviation of the original scale from a representative study. Consistency of findings across individual studies was assessed by standard chi-square tests and the I^2^ statistic.

## RATING THE BODY OF EVIDENCE

SOE was assessed using the approach described in the Agency for Healthcare Research and Quality (AHRQ)'s Methods Guide for Effectiveness and Comparative Effectiveness Reviews.^27^ We focused on the 2 primary outcomes of impact on VMS and health-related quality of life. The AHRQ approach requires assessment of 4 domains: risk of bias, consistency, directness, and precision. Additional domains are used when appropriate: coherence, dose-response association, impact of plausible residual confounders, strength of association (magnitude of effect), and publication bias. These domains were considered qualitatively, and a summary rating of high, moderate, or low SOE was assigned after discussion by 2 investigators. In some cases, a rating of high, moderate, or low was impossible or imprudent to make. In these situations, a rating of insufficient was assigned. This 4-level rating scale consists of the following definitions:

- High—We are confident that the true effect lies close to the estimate of effect.
- Moderate—We are moderately confident of the effect estimate. The true effect is likely to be close to the estimate of effect, but there is a possibility that it is substantially different.
- Low—Our confidence in the effect estimate is limited: The true effect may be substantially different from the estimate of effect.
- Insufficient—We have very little confidence in the effect estimate. The true effect is likely to be substantially different from the estimate of effect.

## PEER REVIEW

This report was reviewed by technical experts and clinical leadership. A transcript of their comments and our responses is provided in Appendix E.