# INTRODUCTION

Hot flashes and night sweats (or vasomotor symptoms) are 2 of the most common symptoms reported during the menopausal transition and are experienced by as many as 80% of women.^1^ The mean age at onset of vasomotor symptoms (VMS) is 51 years,^2^ and recent longitudinal studies of the menopausal transition revealed the median total duration can last more than 7 years.^3^ Women's experience of VMS can vary based on personal characteristics. For example, more African-American women can expect to experience VMS than women from other racial/ethnic groups,^3^ and those who gain weight in midlife are more likely to report hot flashes than those who do not.^4^

Prevalence and duration of VMS in perimenopausal and postmenopausal women are important women's health issues. VMS can lead to increased healthcare encounters for symptom relief^5^ and reductions in quality of life.^6,7^ The impact of VMS on quality of life can be worse for certain populations of women, such as those who undergo surgical rather than natural menopause.^8^ Moreover, the degree to which VMS is bothersome is determined not only by how frequently it occurs but also by other factors such as duration of VMS, coexisting sleep problems,^9^ and the extent to which VMS interferes with daily activities or job-related activities. For some defined populations of women, VMS exerts an especially strong, negative impact on quality of life; this appears to be the case for women Veterans.^6^

Hormone therapy (HT) is an effective treatment for reducing moderate to severe VMS, but use of this therapeutic approach must be individualized through weighing benefits with known risks, such as cardiovascular events or uterine and breast cancers.^10-12^ FDA guidance defines moderate symptoms as “the sensation of heat with sweating, able to continue activity” and severe symptoms as those that cause “cessation of activity.”^13^ A common recommended strategy is to use HT with the “lowest effective dose for the shortest duration that is needed”.^14,15^ Additionally, HT is contraindicated for some women due to comorbid health conditions such as a history of breast cancer or being high risk for development of breast cancer, liver disease, or a history of blood clots. Based on age (> 45 years), currently half of the approximately 360,000 women Veterans who use Veterans Health Administration (VHA) healthcare are perimenopausal or postmenopausal. Many are at increased risk for complications of hormone therapy, such as cardiovascular disease, due to highly prevalent, known risk factors like obesity,^16^ smoking,^17^ and depression.^18^ Despite this, recent evidence indicates that, compared with the general population of women in the United States, women Veterans using VHA are twice as likely to use hormone therapy for relief of menopausal symptoms.^19^

Due to the restriction on long-term hormone therapy use and the extended duration of expected VMS, many women with VMS are left in need of nonhormonal treatment options for many years. Thus, identifying effective nonhormonal interventions for improving quality of life among women Veterans with VMS is an important step to finding safe alternatives to hormone therapy and improved options for Veteran-centered care. Many perimenopausal and postmenopausal women are already using nonpharmacologic agents to manage VMS.^20-22^ Nonpharmacologic treatments for VMS include herbal remedies (eg, black cohosh), mind and body practices (eg, yoga, tai chi), structured exercise programs, and complementary and alternative medicine interventions (eg, acupuncture).^23^

In 2015, an Agency for Healthcare Research and Quality (AHRQ) systematic review^24^ examined the comparative effectiveness of estrogens, isoflavones, selective serotonin reuptake inhibitors/serotonin-norepinephrine reuptake inhibitors, gabapentin, black cohosh, and ginseng for menopausal symptoms, including VMS. However, the AHRQ review did not address nonpharmacologic interventions such as mind and body practices, structured exercise programs, or complementary and alternative medicine interventions. Also in 2015, the North America Menopause Society released a position statement providing recommendations for many such intervention types and graded the level of evidence for their recommendations; however, this was not a formal systematic review of the literature.^25^

Our goal with this report is to summarize and update the evidence from systematic reviews (hereafter referred to as SRs) on selected nonpharmacologic approaches for the treatment of menopause-associated VMS and health-related quality of life.