# APPENDIX E PEER REVIEW COMMENTS/AUTHOR RESPONSES

Reviewer | Comment | Response
Question 1. Are the objectives, scope, and methods for this review clearly described?
1 | Yes | Acknowledged
2 | Yes | Acknowledged
3 | No: I had difficulty with statements like “judged to be of high quality” (p 7, line 48) and “poor quality” (p 7, line 57) that came before the detailed Methods explanation and discussion of how “quality” was judged. This may just be the ESP format but I found it hard to read statements like these w/o knowing more. This is a minor point, but may be best to avoid the statement HT “only for short-term use” as this doesn't encompass newer recommendations to individualize care. These alternative/integrative methods are really a move toward individualization or personalization of health. | We added a statement in the abstract that briefly defines good-and fair-quality reviews. We clarified the statement about current recommendations for duration of HT use to encompass guidance around individualization of care as recommended.
4 | Yes | Acknowledged
Question 2. Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked?
1 | No | Acknowledged
2 | No | Acknowledged
3 | No | Acknowledged
4 | No | Acknowledged
Question 3. Is there any indication of bias in our synthesis of the evidence?
1 | No | Acknowledged
2 | No | Acknowledged
3 | No | Acknowledged
4 | Yes: Lesi et al. J. Clin Onc, 2016 studied acupuncture vs. usual care (included 190 women with breast cancer) | This study was published after our search date and including it in the analysis without completing an updated search for other recently published studies could introduce bias. However, we added a citation to this study in the discussion and note that results were consistent with our review findings.
Question 4: Please write additional suggestions or comments below. If applicable, please indicate the page and line numbers from the draft report.
1 | This is an incredibly extensive and thorough review. It would be helpful to indicate if at all possible if the results from the meta-analysis that were statistically significant translated to clinically meaningful changes in the outcomes (e.g. frequency of VMS). Some of these look quite small and it is difficult to determine whether these changes would make a meaningful difference to women struggling with VMS. | Thank you for this comment. For daily hot flash frequency, which was measured in a consistent manner, we were able to make this transformation. For hot flash severity and health-related quality-of-life, there was too much variability in measurement to make a reliable transformation back to natural units. Although we wanted to add information on the minimum clinically important difference for hot flash frequency, there is no consensus on this value.
2 | Very thorough review of existing SR's and RCTs on topics related to nonpharmacological therapies for VMS. This review was well-written, clear, and described each area very well. Two suggestions: 1. Please add information on the inclusion/exclusion criteria for the SR's and RCTs that were reviewed for this synthesis. 2. Please provide information on the strength of evidence guidelines that were used by the authors--there is a reference to AHRQ's Methods, however, even a short description of what good, fair, etc… entails would be helpful for the reader. Otherwise, well done, comprehensive review. | Eligibility criteria and definitions of the strength of evidence are presented in detail in the Methods section
3 | See above, well written, difficult topic to take on. This provides important contributions to Women's Health. | Thank you.
4 | I had the pleasure reviewing the Non-pharmacological treatment of menopause associated vasomotor symptoms prepared for the Department of Veterans Affairs (Lead author: John Williams). This review is thorough, well-written, with appropriately stated conclusions. I think this will have important implications for improving VM symptom management. A few aspects should be addressed to enhance the quality of this manuscript | Thank you
4 | One new paper just published is highly relevant to this review. Lesi et al. J. Clin Onc, 2016 studied acupuncture vs. usual care (included 190 women with breast cancer) | See response to this comment above.
4 | I am not sure whether there would be enough trials to do a meaningful comparison for acupuncture against non-hormonal based drugs (Gabapentin, Venlafaxine) for effect size, adverse events, and treatment durability. I am aware of at least two such studies. This may be a particularly useful comparison given that for those women who do not want hormones, these are viable options. The authors advocated for comparative effectiveness trials so these analyses (even a qualitative review) may help the authors to be more explicit on what these comparisons should focus on, main effects on hot flashes, adverse effects, durability. | We considered but did not think it appropriate to compare acupuncture with any drug therapy (i.e., drugs from differing classes with differing mechanisms of effect). Our a priori threshold for meta-analysis was 3 trials and comparisons of acupuncture to differing drug classes, and so this did not meet that threshold.
4 | Another aspect is the durability of treatment effect. Currently, this is buried in the text. For women, they want to know if they choose a therapy (acupuncture, yoga, or drugs), if the reduction of their symptoms are durable or they need to get continued treatments. It will be great to summarize these findings as it will have impact on patient quality of life and health care utilization (getting a defined course of acupuncture/drugs will have very different cost implications for VA than getting continued treatment for a long period of time | Thank you for this comment. We have revised the text to more clearly identify timing of outcome assessments and whether the durability of treatment effect was addressed.
4 | Other minor edits
4 | Introduction:
4 | P11line10: change “2” to “two” | Per VA report editorial style, all numbers below 10 (except “one”) are to use numerals.
4 | P11line 22: please add “severity” | This line of the report is in the Data Analysis section of the Methods, which is not concerned with frequency or severity of VMS. Perhaps the reviewer meant a different line. We have carefully reviewed the manuscript to ensure that frequency and severity are used properly and are present where necessary.
4 | In third paragraph of the introduction, please discuss that hormonal treatment is contraindicated for breast cancer survivors or those with high risk for breast cancer | Text was added to note that HT is contraindicated in women with a history of breast cancer or those at high risk for breast cancer.
4 | Page 45: “though it found no difference due to hypnosis when compared to treatment with gabapentin”. I would assume gabapentin is an active control since it has been shown to be more beneficial than placebo for hot flashes | This sentence was adjusted to clarify that gabapentin is an active comparator.