# APPENDIX C QUALITY ASSESSMENT RATINGS

References cited in this appendix appear in the reference list of the main report.

## SYSTEMATIC REVIEWS

Publication | Eligibility Criteria | ID/Select Studies | Data Collection | Synthesis | Overall
Acupuncture
Dodin 2013^40^ | Low | Low | Low | Low | Good
Garcia 2015^41^ | Low | High | Low | Low | Fair
Garcia 2013^64^ | Low | High | Low | Low | Fair
Yoga
Cramer 2012^43^ | Low | Low | Low | Low | Good
Exercise
Daley 2014^44^ | Low | Low | Low | Low | Good
Meditation/Mindfulness/Hypnosis/Relaxation/Mixed
Saensak 2014^45^ | Low | Low | Low | Low | Good
Woods 2014^46^ | Low | Low | High | High | Fair
Cramer 2015^49^ | Low | Low | Low | High | Fair
Innes 2010^47^ | Low | Low | Low | High | Fair
Rada 2010^48^ | Low | Low | Low | Low | Good

## RANDOMIZED CONTROLLED TRIALS

Publication | 1 | 2 | 3 | 4 | 5 | 6 | 7 | 8 | 9 | Overall
Acupuncture
Avis 2016^52^ | LR | LR | HR | LR | LR | Outcome NR | LR | LR | UR | Low
Ee 2016^50^ | LR | LR | LR | LR | LR | LR | LR | LR | LR | Low
Mao 2015^51^ | LR | LR | LR | LR | LR | LR | LR | LR | LR | Low
Nedeljkovic 2014^53^ | LR | LR | LR | LR | LR | UR | LR | LR | UR | Low
Yoga
Avis 2014 ^54^ | UR | UR | HR | LR | UR | UR | LR | LR | HR | High
Ngowsiri 2014^55^ | HR | HR | HR | HR | HR | HR | HR | HR | UR | High
Exercise
Daley 2015^62^ | LR | LR | UR | UR | UR | Outcome NR | LR | LR | HR | Unclear
Duijts 2012^63^ | LR | UR | HR | LR | LR | Outcome NR | LR | LR | LR | Low
Meditation/Mindfulness/Hypnosis/Relaxation/Mixed
Carpenter 2013^56^ | LR | LR | HR | LR | LR | LR | UR | LR | LR | Low
Huang 2015^57^ | LR | LR | LR | LR | UR | UR | LR | LR | LR | Low
Lindh-Astrand 2013^58^ | LR | LR | HR | UR | UR | UR | LR | LR | LR | Unclear
Lindh-Astrand 2015^61^ | LR | LR | HR | LR | Outcome NR | Outcome NR | HR | LR | HR | High
Saensak 2013^59^ | LR | LR | LR | LR | Outcome NR | Outcome NR | LR | LR | HR | Low
Sood 2013^60^ | HR | HR | UR | LR | LR | LR | UR | LR | UR | Unclear

Risk of bias abbreviations: HR = High risk; LR = Low risk; UR = Unclear risk

Column headings:

1. Randomization adequate
2. Allocation concealment
3. Performance bias
4. Detection bias: VMS
5. Detection bias: Health-related quality of life
6. Detection bias: Adverse effects
7. Incomplete outcome
8. Selective outcomes reporting
9. Other bias

### Risk of Bias Summary for New RCTs