# APPENDIX B CRITERIA USED IN QUALITY ASSESSMENT

## SYSTEMATIC REVIEWS

Concerns regarding specifications of eligibility criteria

Low concern | Considerable effort has been made to clearly specify the review question and objectives, and to pre-specify and justify appropriate and detailed eligibility criteria that have been adhered to during the review
High concern | Studies that would have been important and relevant to answering the review question are likely to have been excluded from the review, either due to the lack of pre-specified objectives and eligibility criteria, or because inappropriate restrictions were imposed or studies that are not appropriate for addressing the review question have been included.
Unclear concern | Insufficient information is reported to make a judgement about risk of bias.

Concerns regarding methods used to identify and/or select studies

Low concern | Given the review question and eligibility criteria as assessed in Domain 1, a substantial effort has been made to identify as many relevant studies as possible through a variety of search methods using a sensitive and appropriate search strategy and steps were taken to minimise bias and errors when selecting studies for inclusion.
High concern | Some eligible studies are likely to be missing from the review.
Unclear concern | There is insufficient information reported to make a judgement on risk of bias.

Concerns regarding methods used to collect data and appraise studies

Low concern | Given the studies included in the review as assessed in domain 2, risk of bias was assessed using appropriate criteria, data extraction and risk of bias assessment involved two reviewers, and relevant study characteristics and results were extracted
High concern | Some bias may have been introduced through the data collection or risk of bias assessment processes.
Unclear concerns | There is insufficient information reported to inform a judgement on risk of bias.

Concerns regarding methods used to synthesize results

Low concern | The synthesis is unlikely to produce biased results, because any limitations in the data were overcome, or the findings were so convincing that the limitations would have little impact
High concern | The synthesis is likely to produce biased results, because (i) potential biases were ignored (within and/or across studies), (ii) important between-study variation was not accounted for; (iii) there were important inadequacies in the methodology; or (iv) findings are incompletely reported in a way that raises concerns.
Unclear concerns | There is insufficient information reported to make a judgement on risk of bias.

### References

Marinopoulos SS, Dorman T, Ratanawongsa N, . Effectiveness of continuing medical education. Evid Rep Technol Assess (Full Rep). 2007(149): 1-69.
Moher D, Cook DJ, Eastwood S, Olkin I, Rennie D, Stroup DF. Improving the quality of reports of meta-analyses of randomised controlled trials: the QUOROM statement. Quality of Reporting of Meta-analyses. Lancet. 1999;354(9193): 1896-1900.10584742
Shea BJ, Grimshaw JM, Wells GA, . Development of AMSTAR: a measurement tool to assess the methodological quality of SRs. BMC Medical Research Methodology. 2007;7(1): 1-7.17217545
Whiting P, Savovic J, Higgins JP, . ROBIS: A new tool to assess risk of bias in SRs was developed. J Clin Epidemiol. 2015.

## RANDOMIZED CONTROLLED TRIALS

Risk of Bias | Interpretation | Criteria
Low risk of bias | Bias, if present, is unlikely to alter the results seriously. | Adequacy of random sequence generation, allocation concealment, and blinding scored as “low risk of bias” and no important concerns related to the other domains.
Unclear risk of bias | A risk of bias that raises some doubts about the results | One or two domains are scored “not clear” or not done.
High risk of bias | Bias may alter the results seriously | More than 2 domains are scored as “not clear” or not done

* Items contained in Cochrane Risk of Bias Tool