# APPENDIX A SEARCH STRATEGY

## SYSTEMATIC REVIEWS

### PubMed: November 9, 2015

Search | Query | Items found
#1 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “Menopause”[Mesh] OR menopaus*[tiab] OR “Climacteric”[Mesh:NoExp] OR “Hot Flashes”[Mesh] OR peri-menopaus*[tiab] OR perimenopaus*[tiab] OR postmenopaus*[tiab] OR post-menopaus*[tiab] OR climacteric*[tiab] OR hot-flash*[tiab] OR hot flash*[tiab] OR hot-flush*[tiab] OR hot flush*[tiab] OR night sweat*[tiab] OR vasomotor symptom*[tiab] | 91908
#2 (http://www.ncbi.nlm.nih.gov/pubmed) | Search systematic[sb] OR “Systematic Review”[tiab] OR “Umbrella Review”[tiab] OR meta-analysis[tiab] OR “meta analysis”[tiab] | 280172
#3 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #1 AND #2 | 2771
#4 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “Acupuncture Therapy”[Mesh] OR “Acupuncture”[Mesh] OR “Acupressure”[Mesh] OR “acupuncture”[tiab] OR “acupressure”[tiab] OR “electroacupuncture”[tiab] | 23260
#5 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #3 AND #4 | 45
#6 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “Mind-Body Therapies”[Mesh: NoExp] OR “Mind-Body Therapy”[tiab] OR “Mind Body Therapy”[tiab] OR “Mind-Body Therapies”[tiab] OR “Mind Body Therapies”[tiab] OR “Mind Body Medicine”[tiab] OR “Breathing Exercises”[Mesh] OR “Breathing Exercise”[tiab] OR “Breathing Exercises”[tiab] OR “Respiratory Muscle Training”[tiab] OR “Imagery (Psychotherapy)”[Mesh] OR “Guided Imagery”[tiab] OR “Meditation”[Mesh] OR “Meditation”[tiab] OR “Relaxation Therapy”[Mesh] OR “Relaxation Therapy”[tiab] OR “Relaxation Techniques”[tiab] OR “Relaxation Technique”[tiab] OR “Alexander Technique”[tiab] OR “Mind-Body Relations, Metaphysical”[Mesh] OR “Mindfulness”[Mesh] OR “Mindfulness-based Stress Reduction”[tiab] OR “MBSR”[tiab] OR “paced respiration”[tiab] OR “Hypnosis”[Mesh] OR Hypnoses[tiab] OR Hypnotism[tiab] OR Hypnotherapy[tiab] OR Hypnotherapies[tiab] OR Mesmerism[tiab] | 16823
#7 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #3 AND #6 | 16
#8 (http://www.ncbi.nlm.nih.gov/pubmed) | “Yoga”[Mesh] OR “Yoga”[tiab] OR “Tai Ji”[Mesh] OR “Tai Ji”[tiab] OR “Tai-ji”[tiab] OR “Tai Chi”[tiab] OR “T'ai Chi”[tiab] OR “Taiji”[tiab] OR “Taijiquan”[tiab] OR “Qi Gong”[tiab] OR “Qigong”[tiab] OR “Ch'I Kung”[tiab] | 4440
#9 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #3 AND #8 | 22
#10 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “Exercise”[Mesh:NoExp] OR “Exercise”[Majr] OR “Circuit-Based Exercise”[Mesh] OR “Muscle Stretching Exercises”[Mesh] OR “Physical Conditioning, Human”[Mesh] OR “Resistance Training”[Mesh] OR “Resistance Training”[tiab] OR “Running”[Mesh] OR “Jogging”[Mesh] OR “Swimming”[Mesh] OR “Walking”[Mesh] OR “Exercise”[tiab] OR “Exercises”[tiab] OR “physical activity”[tiab] OR “aerobic activity”[tiab] OR “Exercise Movement Techniques”[Mesh] OR “Sports”[Mesh] | 378950
#11 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #3 AND #10 | 204
#12 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #5 OR #7 OR #9 OR #11 | 247
#13 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#12) AND (“2009/01/01”[Date – Publication] : “3000”[Date – Publication]) | 132
#14 | Search #13 AND “English”[lang] | 123

### EMBASE: November 9, 2015

Search | Query | Items found
#1 (http://www.ncbi.nlm.nih.gov/pubmed) | ‘menopause and climacterium’/exp OR ‘menopause’:ti,ab OR ‘menopausal’:ti,ab OR ‘peri-menopause’:ti,ab OR ‘peri-menopausal’:ti,ab OR ‘perimenopause’:ti,ab OR ‘perimenopausal’:ti,ab OR postmenopause:ti,ab OR postmenopausal:ti,ab OR post-menopause:ti,ab OR post-menopausal:ti,ab OR climacteric:ti,ab OR ‘hot flash’:ti,ab OR ‘hot flashes’:ti,ab OR ‘hot flush’:ti,ab OR ‘hot flushes’:ti,ab OR ‘night sweat’:ti,ab OR ‘night sweats’:ti,ab OR ‘vasomotor symptoms’:ti,ab | 140,141
#2 (http://www.ncbi.nlm.nih.gov/pubmed) | ‘SR’/exp OR ‘meta analysis’/exp OR ‘Systematic Review’:ti,ab OR ‘Umbrella Review’:ti,ab OR ‘meta analysis’:ti,ab | 200,849
#3 (http://www.ncbi.nlm.nih.gov/pubmed) | #1 AND #2 | 2,962
#4 (http://www.ncbi.nlm.nih.gov/pubmed) | ‘acupuncture’/exp OR ‘acupuncture’:ab,ti OR ‘acupressure’:ab,ti OR ‘electroacupuncture’:ab,ti | 37,866
#5 (http://www.ncbi.nlm.nih.gov/pubmed) | #3 AND #4 | 55
#6 (http://www.ncbi.nlm.nih.gov/pubmed) | ‘alternative medicine’/exp OR ‘Mind Body Therapy’:ti,ab OR ‘Mind Body Therapies’:ti,ab OR ‘Mind Body Medicine’:ti,ab OR ‘breathing exercise’/exp OR ‘Breathing Exercise’:ti,ab OR ‘Breathing Exercises’:ti,ab OR ‘Respiratory Muscle Training’:ti,ab OR ‘guided imagery’/exp OR ‘Guided Imagery’:ti,ab OR ‘meditation’/exp OR ‘Meditation’:ti,ab OR ‘transcendental meditation’/exp OR ‘relaxation training’/exp OR ‘relaxation training’:ti,ab OR ‘Relaxation Therapy’:ti,ab OR ‘Relaxation Techniques’:ti,ab OR ‘Relaxation Technique’:ti,ab OR ‘ Alexander Technique’:ti,ab OR ‘mindfulness’/exp OR ‘Mindfulness-based Stress Reduction’:ti,ab OR ‘MBSR’:ti,ab OR ‘paced respiration’:ti,ab OR ‘hypnosis’/exp OR hypnogenesis:ti,ab OR hypnosis:ti,ab OR hypnotism:ti,ab OR mesmerism:ti | 59,899
#7 (http://www.ncbi.nlm.nih.gov/pubmed) | #3 AND #6 | 65
#8 (http://www.ncbi.nlm.nih.gov/pubmed) | ‘Qi Gong’:ti,ab OR ‘Qigong’:ti,ab OR ‘Chi Kung’:ti,ab OR ‘Tai Chi’/exp OR ‘Tai Ji’:ti,ab OR ‘Tai Chi’:ti,ab OR ‘Taiji’:ti,ab OR ‘Taijiquan’:ti,ab OR ‘Yoga’:ti,ab OR ‘kinesiotherapy’/exp | 56,974
#9 (http://www.ncbi.nlm.nih.gov/pubmed) | #3 AND #8 | 60
#10 (http://www.ncbi.nlm.nih.gov/pubmed) | ‘exercise’/exp OR ‘sport’/exp OR ‘Resistance Training’:ti,ab OR ‘Exercise’:ti,ab OR ‘Exercises’:ti,ab OR ‘physical activity’:ti,ab OR ‘aerobic activity’:ti,ab | 510,515
#11 (http://www.ncbi.nlm.nih.gov/pubmed) | #3 AND #10 | 249
#12 (http://www.ncbi.nlm.nih.gov/pubmed) | #5 OR #7 OR #9 OR #11 | 319
#13 | #12 AND [2009-2015]/py | 180
#14 | #13 AND [english]/lim | 173

### Cochrane: November 9, 2015

Search | Query | Items found
#1 (http://www.ncbi.nlm.nih.gov/pubmed) | menopause OR menopausal OR peri-menopause OR peri-menopausal OR perimenopause OR perimenopausal OR postmenopause OR postmenopausal OR post-menopause OR post-menopausal OR climacteric OR hot flash OR hot flashes OR hot flush OR hot flushes OR night sweat OR night sweats OR vasomotor symptoms:ti,ab,kw (Word variations have been searched) | 15991 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#2 | (MH “Acupuncture+”) OR (MH “Alternative Therapies+”) OR (MH “Mind Body Techniques+”) OR (MH “Breathing Exercises+”) OR (MH “Qigong”) OR (MH “Guided Imagery”) OR (MH “Meditation”) OR (MH “Hypnosis+”) OR (MH “Relaxation Techniques+”) OR (MH “Alexander Technique”) OR (MH “Tai Chi”) OR (MH “Mindfulness”) OR (MH “Resistance Training”) OR (MH “Muscle Strengthening+”) OR (MH “Therapeutic Exercise+”) OR (MH “Exercise+”) OR (MH “Sports+”) OR (MH “Physical Activity”) OR TI (acupuncture OR acupressure OR electroacupuncture OR “alternative medicine” OR “Mind Body Therapy” OR “Mind Body Therapies” OR “Mind Body Medicine” OR “Breathing Exercise” OR “Breathing Exercises” OR “Qi Gong” OR Qigong OR “Chi Kung” OR “Respiratory Muscle Training” OR “Guided Imagery” OR Meditation OR “relaxation training” OR “Relaxation Therapy” OR “Relaxation Techniques” OR “Relaxation Technique” OR hypnosis OR “Alexander Technique” OR “Tai Ji” OR “Tai Chi” OR Taiji OR Taijiquan OR Yoga OR “Mindfulness-based Stress Reduction” OR MBSR OR “paced respiration” OR sport OR “Resistance Training” OR Exercise OR Exercises OR “physical activity” OR “aerobic activity”) OR AB (acupuncture OR acupressure OR electroacupuncture OR “alternative medicine” OR “Mind Body Therapy” OR “Mind Body Therapies” OR “Mind Body Medicine” OR “Breathing Exercise” OR “Breathing Exercises” OR “Qi Gong” OR Qigong OR “Chi Kung” OR “Respiratory Muscle Training” OR “Guided Imagery” OR Meditation OR “relaxation training” OR “Relaxation Therapy” OR “Relaxation Techniques” OR “Relaxation Technique” OR hypnosis OR “Alexander Technique” OR “Tai Ji” OR “Tai Chi” OR Taiji OR Taijiquan OR Yoga OR “Mindfulness-based Stress Reduction” OR MBSR OR “paced respiration” OR sport OR “Resistance Training” OR Exercise OR Exercises OR “physical activity” OR “aerobic activity”) (Word variations have been searched) | 72084
#3 | #1 AND #2 Publication Year from 2009 to 2015 | 806
#4 | #3 Cochrane Reviews: 15 Other Reviews: 23 | 38

## RANDOMIZED CONTROLLED TRIALS

### PubMed: February 12, 2016

Search | Query | Items found
#1 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “Menopause”[Mesh] OR menopaus*[tiab] OR “Climacteric”[Mesh:NoExp] OR “Hot Flashes”[Mesh] OR peri-menopaus*[tiab] OR perimenopaus*[tiab] OR postmenopaus*[tiab] OR post-menopaus*[tiab] OR climacteric*[tiab] OR hot-flash*[tiab] OR hot flash*[tiab] OR hot-flush*[tiab] OR hot flush*[tiab] OR night sweat*[tiab] OR vasomotor symptom*[tiab] | 92983 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#2 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (randomized controlled trial[pt] OR controlled clinical trial[pt] OR randomized[tiab] OR randomised[tiab] OR randomization[tiab] OR randomisation[tiab] OR placebo[tiab] OR drug therapy[sh] OR randomly[tiab] OR trial[tiab] OR groups[tiab]) NOT (animals[mh] NOT humans[mh]) NOT (Editorial[ptyp] OR Letter[ptyp] OR Case Reports[ptyp] OR Comment[ptyp]) | 2838660 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#3 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #1 AND #2 | 33136 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#4 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “Acupuncture Therapy”[Mesh] OR “Acupuncture”[Mesh] OR “Acupressure”[Mesh] OR “acupuncture”[tiab] OR “acupressure”[tiab] OR “electroacupuncture”[tiab] | 23994 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#5 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #3 AND #4 | 186 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#6 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “Mind-Body Therapies”[Mesh: NoExp] OR “Mind-Body Therapy”[tiab] OR “Mind Body Therapy”[tiab] OR “Mind-Body Therapies”[tiab] OR “Mind Body Therapies”[tiab] OR “Mind Body Medicine”[tiab] OR “Breathing Exercises”[Mesh] OR “Breathing Exercise”[tiab] OR “Breathing Exercises”[tiab] OR “Respiratory Muscle Training”[tiab] OR “Imagery (Psychotherapy)”[Mesh] OR “Guided Imagery”[tiab] OR “Meditation”[Mesh] OR “Meditation”[tiab] OR “Relaxation Therapy”[Mesh] OR “Relaxation Therapy”[tiab] OR “Relaxation Techniques”[tiab] OR “Relaxation Technique”[tiab] OR “Alexander Technique”[tiab] OR “Mind-Body Relations, Metaphysical”[Mesh] OR “Mindfulness”[Mesh] OR “Mindfulness-based Stress Reduction”[tiab] OR “MBSR”[tiab] OR “paced respiration”[tiab] OR “Hypnosis”[Mesh] OR Hypnoses[tiab] OR Hypnotism[tiab] OR Hypnotherapy[tiab] OR Hypnotherapies[tiab] OR Mesmerism[tiab] | 28100 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#7 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #3 AND #6 | 79 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7)
#8 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “Yoga”[Mesh] OR “Yoga”[tiab] OR “Tai Ji”[Mesh] OR “Tai Ji”[tiab] OR “Tai-ji”[tiab] OR “Tai Chi”[tiab] OR “T'ai Chi”[tiab] OR “Taiji”[tiab] OR “Taijiquan”[tiab] OR “Qi Gong”[tiab] OR “Qigong”[tiab] OR “Ch'I Kung”[tiab] | 4576 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=8)
#9 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #3 AND #8 | 84 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=9)
#10 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “Exercise”[Mesh:NoExp] OR “Exercise”[Majr] OR “Circuit-Based Exercise”[Mesh] OR “Muscle Stretching Exercises”[Mesh] OR “Physical Conditioning, Human”[Mesh] OR “Resistance Training”[Mesh] OR “Resistance Training”[tiab] OR “Running”[Mesh] OR “Jogging”[Mesh] OR “Swimming”[Mesh] OR “Walking”[Mesh] OR “Exercise”[tiab] OR “Exercises”[tiab] OR “physical activity”[tiab] OR “aerobic activity”[tiab] OR “Exercise Movement Techniques”[Mesh] OR “Sports”[Mesh] | 387613 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=10)
#11 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #3 AND #10 | 2129 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=11)
#12 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #5 OR #7 OR #9 OR #11 | 2338 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=12)
#13 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #12 AND (“2012/01/01”[Date – Publication] : “3000”[Date – Publication]) | 653 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=13)
#14 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #13 AND “English”[lang] Sort by: Author | 612 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=14)

### EMBASE: February 12, 2016

Search | Query | Items found
#1 (http://www.ncbi.nlm.nih.gov/pubmed) | ‘menopause and climacterium’/exp OR ‘menopause’:ti,ab OR ‘menopausal’:ti,ab OR ‘peri-menopause’:ti,ab OR ‘peri-menopausal’:ti,ab OR ‘perimenopause’:ti,ab OR ‘perimenopausal’:ti,ab OR postmenopause:ti,ab OR postmenopausal:ti,ab OR post-menopause:ti,ab OR post-menopausal:ti,ab OR climacteric:ti,ab OR ‘hot flash’:ti,ab OR ‘hot flashes’:ti,ab OR ‘hot flush’:ti,ab OR ‘hot flushes’:ti,ab OR ‘night sweat’:ti,ab OR ‘night sweats’:ti,ab OR ‘vasomotor symptoms’:ti,ab | 142,022
#2 (http://www.ncbi.nlm.nih.gov/pubmed) | ((‘randomized controlled trial’/exp OR ‘crossover procedure’/exp OR ‘double blind procedure’/exp OR ‘single blind procedure’/exp OR random* OR factorial* OR crossover* OR cross NEAR/1 over* OR placebo* OR doubl* NEAR/1 blind* OR singl* NEAR/1 blind* OR assign* OR allocat* OR volunteer*) NOT (‘case report’/exp OR ‘case study’/exp OR ‘editorial’/exp OR ‘letter’/exp OR ‘note’/exp OR ‘conference paper’/exp)) AND ([humans]/lim AND [english]/lim AND [2012-2016]/py) | 428,259
#3 (http://www.ncbi.nlm.nih.gov/pubmed) | #1 AND #2 | 6,358
#4 (http://www.ncbi.nlm.nih.gov/pubmed) | ‘acupuncture’/exp OR ‘acupuncture’:ab,ti OR ‘acupressure’:ab,ti OR ‘electroacupuncture’:ab,ti OR ‘alternative medicine’/exp OR ‘Mind Body Therapy’:ti,ab OR ‘Mind Body Therapies’:ti,ab OR ‘Mind Body Medicine’:ti,ab OR ‘breathing exercise’/exp OR ‘Breathing Exercise’:ti,ab OR ‘Breathing Exercises’:ti,ab OR ‘Respiratory Muscle Training’:ti,ab OR ‘guided imagery’/exp OR ‘Guided Imagery’:ti,ab OR ‘meditation’/exp OR ‘Meditation’:ti,ab OR ‘transcendental meditation’/exp OR ‘relaxation training’/exp OR ‘relaxation training’:ti,ab OR ‘Relaxation Therapy’:ti,ab OR ‘Relaxation Techniques’:ti,ab OR ‘Relaxation Technique’:ti,ab OR ‘ Alexander Technique’:ti,ab OR ‘mindfulness’/exp OR ‘Mindfulness-based Stress Reduction’:ti,ab OR ‘MBSR’:ti,ab OR ‘paced respiration’:ti,ab OR ‘hypnosis’/exp OR hypnogenesis:ti,ab OR hypnosis:ti,ab OR hypnotism:ti,ab OR mesmerism:ti,ab OR ‘Qi Gong’:ti,ab OR ‘Qigong’:ti,ab OR ‘Chi Kung’:ti,ab OR ‘Tai Chi’/exp OR ‘Tai Ji’:ti,ab OR ‘Tai Chi’:ti,ab OR ‘Taiji’:ti,ab OR ‘Taijiquan’:ti,ab OR ‘Yoga’:ti,ab OR ‘kinesiotherapy’/exp OR ‘exercise’/exp OR ‘sport’/exp OR ‘Resistance Training’:ti,ab OR ‘Exercise’:ti,ab OR ‘Exercises’:ti,ab OR ‘physical activity’:ti,ab OR ‘aerobic activity’:ti,ab | 630,791
#4 | #3 AND #4 | 849

### CINAHL: February 12, 2016

Search | Query | Items found
S1 (http://www.ncbi.nlm.nih.gov/pubmed) | (MH “Menopause+”) OR TI ( menopause OR menopausal OR “peri-menopause” OR “peri-menopausal” OR perimenopause OR perimenopausal OR postmenopause OR postmenopausal OR “post-menopause” OR “post-menopausal” OR climacteric OR “hot flash” OR “hot flashes” OR “hot flush” OR “hot flushes” OR “night sweat” OR “night sweats” OR “vasomotor symptoms” ) OR AB ( menopause OR menopausal OR “peri-menopause” OR “peri-menopausal” OR perimenopause OR perimenopausal OR postmenopause OR postmenopausal OR “post-menopause” OR “post-menopausal” OR climacteric OR “hot flash” OR “hot flashes” OR “hot flush” OR “hot flushes” OR “night sweat” OR “night sweats” OR “vasomotor symptoms” ) | 22,202
S2 | (MH “Acupuncture+”) OR (MH “Alternative Therapies+”) OR (MH “Mind Body Techniques+”) OR (MH “Breathing Exercises+”) OR (MH “Qigong”) OR (MH “Guided Imagery”) OR (MH “Meditation”) OR (MH “Hypnosis+”) OR (MH “Relaxation Techniques+”) OR (MH “Alexander Technique”) OR (MH “Tai Chi”) OR (MH “Mindfulness”) OR (MH “Resistance Training”) OR (MH “Muscle Strengthening+”) OR (MH “Therapeutic Exercise+”) OR (MH “Exercise+”) OR (MH “Sports+”) OR (MH “Physical Activity”) OR TI (acupuncture OR acupressure OR electroacupuncture OR “alternative medicine” OR “Mind Body Therapy” OR “Mind Body Therapies” OR “Mind Body Medicine” OR “Breathing Exercise” OR “Breathing Exercises” OR “Qi Gong” OR Qigong OR “Chi Kung” OR “Respiratory Muscle Training” OR “Guided Imagery” OR Meditation OR “relaxation training” OR “Relaxation Therapy” OR “Relaxation Techniques” OR “Relaxation Technique” OR hypnosis OR “Alexander Technique” OR “Tai Ji” OR “Tai Chi” OR Taiji OR Taijiquan OR Yoga OR “Mindfulness-based Stress Reduction” OR MBSR OR “paced respiration” OR sport OR “Resistance Training” OR Exercise OR Exercises OR “physical activity” OR “aerobic activity”) OR AB (acupuncture OR acupressure OR electroacupuncture OR “alternative medicine” OR “Mind Body Therapy” OR “Mind Body Therapies” OR “Mind Body Medicine” OR “Breathing Exercise” OR “Breathing Exercises” OR “Qi Gong” OR Qigong OR “Chi Kung” OR “Respiratory Muscle Training” OR “Guided Imagery” OR Meditation OR “relaxation training” OR “Relaxation Therapy” OR “Relaxation Techniques” OR “Relaxation Technique” OR hypnosis OR “Alexander Technique” OR “Tai Ji” OR “Tai Chi” OR Taiji OR Taijiquan OR Yoga OR “Mindfulness-based Stress Reduction” OR MBSR OR “paced respiration” OR sport OR “Resistance Training” OR Exercise OR Exercises OR “physical activity” OR “aerobic activity”) | 341,974
S3 | S1 AND S2 Published Date: 20120101-20160231 | 1,029
S4 | TI (“randomized controlled trial” OR “controlled clinical trial” OR “randomized” OR “randomized” OR “randomization” OR “randomization” OR “placebo” OR “randomly” OR “trial” OR “groups” OR AB (“randomized controlled trial” OR “controlled clinical trial” OR “randomized” OR “randomized” OR “randomization” OR “randomization” OR “placebo” OR “randomly” OR “trial” OR “groups”) OR (MH “Randomized Controlled Trials”) | 391,791
S5 | S3 AND S4 | 345
S6 | S5 NOT PT (Book OR Book Chapter OR Book Review OR Case Study OR Commentary OR Doctoral Dissertation OR Editorial OR Letter OR Masters Thesis OR Pamphlet OR Pamphlet Chapter OR Poetry) | 339