# SUMMARY AND DISCUSSION

The Mediterranean diet was first described over 50 years ago by Ancel Keys.1 Interest in this diet has intensified in recent years as many developed and developing countries confront a dramatic increase in obesity and chronic diseases linked to consumption of a typical Western diet rich in red meat, dairy products, processed and artificially sweetened foods, and salt.112 In contrast, the diet typically consumed in Mediterranean countries in the 1960s emphasized consumption of olive oil, fruits, vegetables, legumes, and whole grains. Many epidemiologic studies, and more recently RCTs, have investigated the effect of this diet on incidence of, and morbidity from, common chronic conditions such as cardiovascular disease, T2DM, and cancer.3-8 The purpose of this review was to provide an updated summary of the available evidence on the health benefits of the Mediterranean diet.

The Key Questions we addressed were:

Key Question 1: Is the Mediterranean diet more effective than other diets in preventing death or the development of type 2 diabetes mellitus, cardiovascular disease, cancer, hypertension, cognitive impairment, or kidney disease?

- Key Question 1a: Do the effects vary by gender, age, or BMI?

Key Question 2: Compared to other diets, is the Mediterranean diet associated with fewer adverse outcomes (including death) or less disease progression in people who already have diabetes, cardiovascular disease, cancer, hypertension, cognitive impairment, rheumatoid arthritis, or kidney disease?

- Key Question 2a: Do the effects vary by gender, age, or BMI?

Key Question 3: What is the observed adherence to the Mediterranean diet in studies conducted in the United States or Canada?

## OVERVIEW OF METHODS

This systematic review included a total of 55 studies published in English between 1990 and August 2015 that enrolled free-living, non-pregnant, non-lactating adults. We included RCTs that enrolled at least 100 people and followed them for at least a year. For select outcomes (cancer, cognitive impairment, and rheumatoid arthritis) we also included cohort studies.

We included studies whose diets met the criteria used in a recent Cochrane Review17 (ie, labelled a Mediterranean diet or meeting 2 or more of the following components: 1. high monounsaturated:saturated fat ratio (use of olive oil as main cooking ingredient); 2. high consumption of fruits/vegetables; 3. high consumption of legumes; 4. high consumption of grains/cereals; 5. moderate red wine consumption; 6. moderate consumption of dairy products; and 7. low consumption of meat and meat products replaced by increased consumption of fish). All included studies met this minimum definition. The names for the diets included terms such as Mediterranean diet, prudent diet, healthy Nordic diet, and healthy pattern.

## SUMMARY OF EVIDENCE BY KEY QUESTION

### KQ1 Primary Prevention

We identified 42 studies (3 RCTs and 39 cohort studies) that reported the association between conformity to a Mediterranean diet and the occurrence of outcomes in over 2 million people without a history of the outcome of interest (primary prevention). We found no studies reporting new onset kidney disease or hypertension.

Cardiovascular disease and all-cause mortality (RCTs only). Three trials that included a total of 56,711 people evaluated the effect of the Mediterranean diet on major cardiovascular outcomes (MI, stroke, and CV death) and all-cause mortality.7,23,24,32 All-cause mortality was similar between diet groups in the 2 trials that reported statistical significance.7,23

The PREvencion con DIeta MEDiterranea (PREDIMED) was a Spanish trial of 7,447 people randomized to either a Mediterranean diet with supplemental extra virgin olive oil, a Mediterranean diet supplemented with nuts, or a low-fat control diet. Both of the intervention diets included 5 of the 7 components in our Mediterranean diet definition. After an average follow-up of 4.8 years, both intervention groups had a significant 30% reduction in major cardiovascular events compared to the control group. When the individual components of the composite endpoint were evaluated, only stroke was significantly reduced in the Mediterranean diet group compared to the control group.

The WHI-DM was a US trial of 48,835 women, aged 50-79, assigned either a low-fat diet (which included 2 of the 7 components of the Mediterranean diet) or a usual diet control. After an average follow-up of 8.1 years, there was no significant reduction in major cardiovascular events (either as a composite or individually) in the group assigned to the intervention diet.

Disparate results in these 2 trials may reflect differences in the diets evaluated. In PREDIMED the intervention diet included 5 of the 7 Mediterranean diet components and the control was a low-fat diet. In contrast, in WHI-DM the intervention group received a low-fat diet (which included advice to increase fruit and vegetable and grain intake and thus met our definition of a Mediterranean diet) whereas the control group received general advice only. The fact that the intervention diet in WHI-DM is more similar to the PREDIMED control diet than to the PREDIMED intervention diet may explain why WHI-DM found no benefit and PREDIMED did.

A recent Cochrane review (N = 52,044; k = 11) evaluated the efficacy of a Mediterranean diet for primary prevention of cardiovascular disease.17 This review included only RCTs of at least 3 months duration with a control group that received either no or only a minimal intervention. RCTs reporting only laboratory endpoints were included. The only study included in both the Cochrane review and the present review was the WHI-DM. Of note, the Cochrane review did not include the PREDIMED study because the comparator intervention did not meet the criterion of “no or minimal” intervention.

We did not include cohort studies in our analysis of total mortality or cardiovascular outcomes. A recent review of prospective cohort studies that included a total of 4.2 million participants without a history of cardiovascular disease reported that a 2-point increase in a Mediterranean diet conformity score was associated with an 8% reduction in all-cause mortality (RR 0.92, 95% CI 0.87, 0.92) and a 10% decrease in cardiovascular disease incidence and/or mortality (RR 0.90, 95% CI 0.87, 0.92).18 In addition, a recent meta-analysis that included primary and secondary prevention case-control, cross-sectional, and cohort studies (N = 162,092; k = 9) found that higher conformity to a Mediterranean diet (ie, a score of 6 to 9 on the Mediterranean-diet score) was associated with a significant 29% reduction in stroke risk (0.71, 95% CI 0.57, 0.89).4,16

Type 2 diabetes mellitus (RCTs only). T2DM was reported in 2 RCTs (N = 49,428), PREDIMED and WHI-DM.26,30 In WHI-DM there was a similar incidence of T2DM in the intervention and control diet groups.30 In PREDIMED the incidence of T2DM over 4.1 years of follow-up in people who did not have T2DM at baseline (N = 3,541) was significantly reduced compared to the control diet in the group randomized to the Mediterranean diet supplemented with EVOO (HR 0.60, 95% CI 0.43, 0.85) but not the Mediterranean diet supplemented with nuts (0.82, 95% CI 0.61, 1.10).26 The disparate findings between WHI-DM and PREDIMED may be related to the differences in these 2 studies' dietary interventions, as discussed above.

A recent systematic review evaluated the association between conformity to the Mediterranean diet and development of T2DM. A pooled analysis of one clinical trial (a single-site report from PREDIMED) and 9 prospective cohort studies (N = 136,846) found a significant association between people with the highest versus lowest conformity to the Mediterranean diet and incidence of T2DM (RR 0.77, 95% CI 0.66, 0.89).10

Cancer (RCTs and cohort studies). Two RCTs reported cancer outcomes.23,27,31 The WHI-DM found no difference in total cancer incidence or mortality. It also reported no difference in colorectal cancer mortality or incidence of breast, colorectal, skin, ovarian, uterine or other cancers between the 2 diet groups. The PREDIMED trial reported a decreased risk of breast cancer in participants assigned the Mediterranean diet supplemented with extra virgin olive oils as compared to the control diet (HR 0.32, 95% CI 0.13, 0.79).

Results of the 28 cohort studies that reported cancer outcomes, comparing highest to lowest Mediterranean diet conformity, are summarized below:

- [underlined: Total cancer]: Significant 4% reduction in incidence (k = 3) and significant 14% reduction in mortality (k = 13)
- [underlined: Breast cancer]: No reduction in breast cancer incidence (k = 13) or mortality (k = 1)
- [underlined: Colorectal cancer]: Significant 9% reduction in incidence (k = 9); no reduction in mortality (k = 1)
- [underlined: Other cancers]:
  ○ No reduction in ovarian (k = 1), pancreatic (k = 2), head and neck (k = 1), lung (k = 1), bladder (k = 1), gastric (k = 2), or prostate (k = 3), cancer incidence
  ○ No reduction in pancreatic (k = 1), stomach (k = 1), prostate (k = 2), or respiratory tract (k = 1) cancer mortality

Our findings from the observational data that [underlined: total cancer incidence and mortality] and [underlined: colorectal cancer incidence] were significantly lower in those with the highest conformity to a Mediterranean diet compared to lowest conformity is consistent with findings from a recent systematic review.18 These findings, however, were not confirmed by the WHI-DM. Although this difference is likely due to the fact that cohort studies are subject to confounding, it is also possible that a RCT that utilized a more intensive Mediterranean diet intervention than was used in WHI-DM would have corroborated the cohort studies. As noted above, PREDIMED, which did test an intensive Mediterranean diet intervention, reported a significant reduction in breast cancer incidence in the intervention group.

Cognitive impairment. Data from the 2 identified RCTs were mixed.24,25,28 One site of the PREDIMED trial reported reductions in mild cognitive impairment and dementia in the Mediterranean diet groups compared to control diet while another site reported no associations between diet and cognitive outcomes.25,28 An RCT in Hong Kong found similar rates of development of dementia after about 3 years of follow-up in 429 participants age ≥ 75 who had been randomized to either a diet high in fruits, vegetables, and fish or a control diet.24 Results from the cohort studies were also mixed although most studies reporting quantiles of Mediterranean-diet score found no association between diet and cognitive impairment.

Rheumatoid arthritis. One cohort study which enrolled 174,638 female registered nurses found similar rates of rheumatoid arthritis in participants with the highest and lowest Mediterranean diet scores (HR 0.98, 95% CI 0.8, 1.2).93

Gender, age, or BMI. Several studies reported outcomes stratified by gender, age, or BMI groups. Findings were inconsistent.

### KQ2 Secondary Prevention

We identified 15 studies (8 RCTs and 7 cohort studies, N = 19,972) that reported the association between conformity to a Mediterranean diet and the occurrence of outcomes in those with the condition of interest at baseline (secondary prevention). No studies reported kidney disease, hypertension or diabetes. [underlined: Of note, there is credible although not definitive evidence that 3 of the RCTs may contain fraudulent data.]98-100,103 [underlined: Therefore we have not included those data in our summary, below].

Cardiovascular disease, cardiovascular mortality, and all-cause mortality. Pooled results from 3 RCTs that enrolled people with cardiovascular disease at baseline showed similar all-cause mortality in those assigned the Mediterranean diet compared to those assigned a control diet.6,8,94,97

Pooled data from 2 of the 3 RCTs showed that randomization to a Mediterranean diet significantly reduced the risk of myocardial infarction.6,8 Pooled data showed similar incidence of cardiovascular mortality (k = 2), stroke (k = 2), and revascularization procedures (k = 3) in the 2 diet intervention groups.6,8,94,96,97

Of note, all 3 RCTs had substantial limitations. The Lyon Heart Study was the strongest methodologically but it included only 605 people.6,95-97 The Welsh trial enrolled over 3,000 men but was interrupted by funding problems, leading to convoluted analyses.94 The Spokane, Washington trial enrolled only 101 patients.8

We did not include studies whose only outcome was cardiac risk factors, but other systematic reviews have found that the Mediterranean diet is associated with significant reductions in total and LDL cholesterol, body weight, blood pressure, fasting plasma glucose, and C-reactive protein.14,17

Cancer. In 6 cohort studies that examined outcomes in people with colon cancer (k = 2), breast cancer (k = 3), or prostate cancer (k = 2) there was a similar incidence of cancer recurrence and cancer-specific mortality in those with the highest compared to the lowest conformity to a Mediterranean diet.41,104-110

Cognitive impairment. One cohort study in New York that enrolled 482 people with mild cognitive impairment reported similar incidence of progression to Alzheimer's disease in those with higher conformity compared to lower conformity to a Mediterranean diet.87

Rheumatoid arthritis. Two small trials of a Mediterranean diet compared to a usual diet (n = 51, 12 week follow-up and n = 130, 26 week follow-up) reported significant improvement in global pain and functional status questionnaire scores. The smaller and shorter trial reported significant improvement in a disease activity score but the larger, longer one did not.101,102

### KQ3 Adherence

Two RCTs conducted in the United States reported data on adherence.111,113 Results from these trials show that in the context of a randomized trial with intensive behavioral interventions it is possible to achieve sustained increases in consumption of fruits and vegetables and grains (2 components of the Mediterranean diet). Whether the same results could be achieved in a general population and without a labor-intensive behavioral intervention is not known.

A recent systematic review summarized the effects of interventions to promote a Mediterranean diet or healthy eating pattern in primary health care settings.12 This review included only RCTs but did not require enrollment of at least 100 subjects or follow-up of at least one year. Fourteen studies were included, only 2 of which studied a Mediterranean diet. Neither of these studies was included in our review as one was conducted in Spain and one in inpatients in the United Kingdom.114,115 The review concluded that there is moderate evidence that nutritional counselling moderately increases intake of fruits and vegetables and that more intensive interventions with more frequent patient contact are most effective.

## APPLICABILITY OF FINDINGS TO THE VA POPULATION

Although the data are limited in that there were few randomized controlled trials and the majority of included studies (whether trials or cohort studies) were not conducted in North American populations, we believe that the available outcome data are applicable to the general VA population.

## RESEARCH GAPS/FUTURE RESEARCH

A major gap is the absence of large-scale clinical outcomes trials of a Mediterranean diet in North American populations, both in primary and secondary prevention populations. Such trials are important both to confirm results of the few trials performed abroad and to determine the acceptability of the Mediterranean diet to the American public. In addition, the following areas represent important avenues for future research:

- modeling studies to ascertain if specific components or combination of components of the Mediterranean diet are more protective than others;
- barriers to adoption of a Mediterranean diet in people used to consuming a traditional Western diet and interventions to address those barriers; and
- relative advantages of the Mediterranean diets compared to other healthy diets (eg, DASH diet).

## STRENGTH OF EVIDENCE

The strength of evidence was low or insufficient for all outcomes evaluated.

## CONCLUSIONS

In this systematic review and meta-analysis of 55 published studies we identified a single [underlined: primary prevention] trial which found that consumption of a Mediterranean diet was associated with a significant reduction in major cardiac events, new onset T2DM, and breast cancer incidence. For [underlined: secondary prevention], data from 2 trials indicate that assignment to a Mediterranean diet reduces incidence of myocardial infarction but not other cardiovascular outcomes. Cohort studies indicate that conformity to a Mediterranean diet pattern is associated with significant reduction in total cancer incidence, total cancer mortality, and colorectal cancer incidence. These associations have not been confirmed in RCTs. Available data on other outcomes, such as cognitive impairment and rheumatoid arthritis, were limited. The available data on dietary [underlined: adherence] suggest that sustained increases in consumption of fruits and vegetables and grains can be achieved with labor intensive behavioral interventions in select populations.