# RESULTS

## LITERATURE FLOW

The overall literature flow is presented below. Literature flows for each of the Key Questions are presented in Appendix D. We reviewed a total of 9,602 abstracts.

Figure 2 Overall Literature Flow (KQ1-3)

^a^ Studies may have presented data for more than one KQ.

## KEY QUESTION 1 Is the Mediterranean diet more effective than other diets in preventing death or the development of Type II diabetes mellitus, cardiovascular disease, cancer, hypertension, cognitive impairment, or kidney disease?

### Overview of Studies (Table 1 and Appendix C, Table 1)

Table 1 Summary of Included Studies - Key Question 1

Characteristic | Mean (range) Unless Otherwise Noted | Number of Studies Reporting^a^
Total number of patients evaluated | 2,489,225 (429 to 566,407) | 42
Randomized controlled trials, total number of patients | 56,711 (429 to 48,835) | 3
Cohort studies, total number of patients | 2,432,514 (723 to 566,407) | 39
Age of subjects, years | 61 (36 to 83) | 28
Gender, % male patients in mixed gender studies | 46% (15% to 66%) | 23^c^
Mixed gender studies, total number of patients | 1,571,038 (429 to 566,407) | 23
Male only studies, total number of patients | 79,265 (1,044 to 47,867) | 4
Female only studies, total number of patients | 838,922 (3,220 to 174,638) | 15^d^
Body Mass Index | 26 (23 to 30) | 25
Location - USA/Canada, total number of patients | 1,487,412 (826 to 494,968) | 21^d^
Location - Europe, total number of patients | 956,992 (1,044 to 566,407) | 17^b^
Location - Asia/Australia, total number of patients | 44,821 (429 to 42,112) | 4^c^

a Footnotes indicate RCTs represented in number of studies:

b PREDIMED,7,25-28

c Kwok 2012,^24^

d WHI-DM23,29-32

We identified a total of 72 articles reporting results from 42 studies. Three were randomized controlled trials and 39 were cohort studies. The dietary interventions used in the 3 RCTs are detailed in the sections below entitled all-cause mortality and cognitive functioning. The cohort studies employed a variety of scales to rate each individual's degree of conformity to the Mediterranean diet (see Methods section).

We extracted all-cause mortality (number of studies reporting[k] = 3), cardiovascular outcomes (k = 2), and T2DM (k = 2) only from RCTs. We extracted cancer outcomes from both cohort studies (k = 28) and RCTs (k = 2), cognitive impairment from both cohort studies (k = 13) and RCTs (k = 2), and rheumatoid arthritis from one cohort study. No studies reported new-onset kidney disease or hypertension, or quality of life. Twenty one studies were conducted in North America, 17 in Europe, and 4 in Asia or Australia. The total number of participants was 2,489,225 with a range of sample sizes from 429 to 566,407. The average age of participants was 61 (k = 28) and the mean BMI was 26 (k = 25). For studies using mixed gender cohorts the mean percentage of men was 46% (k = 23).

### Outcomes (Appendix C, Tables 1 – 4)

#### All-Cause Mortality (RCTs only)

All-cause mortality was reported in 3 trials [WHI-DM, PREDIMED, and a smaller study from Hong Kong; total N = 56,711].7,23,24 PREDIMED was a multicenter trial in Spain that randomized 7,447 people to one of 3 diets: Mediterranean diet supplemented with extra virgin olive oil (EVOO), Mediterranean diet supplemented with mixed nuts, or a control diet. Each of the 2 intervention diets comprised 5 of the 7 components of a Mediterranean diet, including olive oil. The mean age of enrollees was 67 years, 57% were women, 97% were Caucasian, 25% were former and 14% were current smokers, the mean body mass index was 29.8, 82% had hypertension, 50% had diabetes, and 70% had dyslipidemia.7 Median follow-up was 4.8 years. The primary endpoint was major cardiovascular events (myocardial infarction, stroke, or cardiovascular death).

The second trial was the WHI-DM, a multi-center trial which randomized 48,835 postmenopausal women to either a usual diet control or a dietary intervention which included goals of total fat intake of <20% of total calories, 5 or more servings per day of fruits and vegetables, and 6 or more servings per day of grains (ie, 2 of the 7 components of a Mediterranean diet).23 Ninety-seven percent of participants had no history of cardiovascular disease at baseline. Participants were followed for an average of 8.1 years. There was no association between diet group and total mortality in either trial.

The third study followed 429 residents of 14 old-age hostels in Hong Kong for 33 months.24 The intervention group received a diet containing 2 of the 7 Mediterranean diet components: fruit/vegetables and fish. The mortality rate was 13% (27/204) in the group following a Mediterranean diet compared to 11% (25/225) in the control group the statistical significance of this finding was not reported.

#### Cardiovascular Disease (RCTs only)

Cardiovascular disease outcomes were reported in 2 trials, described above [WHI-DM, PREDIMED, N = 56,282]. The primary endpoint in PREDIMED was major cardiovascular events (myocardial infarction, stroke, or cardiovascular death). Compared to the control diet, both Mediterranean diets were associated with a significant 30% reduction in the primary endpoint (HR 0.70, 95% CI 0.54, 0.92 for EVOO and HR 0.72, 95% CI 0.54, 0.96 for nuts).7 When the 3 components of this composite endpoint were evaluated individually, only the reduction in stroke risk was significant (HR 0.68, 95% CI 0.49, 0.96).7 There was no significant difference between the 2 Mediterranean diets.7 In WHI-DM, the incidence of all major cardiovascular outcomes reported (including myocardial infarction, CHD death, stroke, revascularization procedures, and various combinations of these outcomes) was similar between the 2 intervention groups.32

#### Type 2 Diabetes Mellitus (RCTs only)

T2DM was reported in 2 trials that included a total of 49,428 people. The PREDIMED study (described above) reported a subgroup analysis based on 3541 participants who did not have T2DM when enrolled in the trial.26 Compared to the control diet, persons randomized to the Mediterranean diet supplemented with extra virgin olive oil had a significant reduction in risk of developing T2DM over a median 4.1 years of follow-up (HR 0.60, 95% CI 0.43, 0.85).26 Those randomized to the Mediterranean diet supplemented with nuts had a non-significant reduction in risk of developing T2DM (HR 0.82, 95% CI 0.61, 1.10).

The second trial reporting T2DM as an outcome was the WHI-DM, described above.30 The incidence of new onset T2DM was similar between the 2 diet groups (HR 0.96, 95% CI 0.90, 1.03).

#### Cancer (RCTS and cohort studies)

Cancer as an outcome was reported in 30 studies, 2 RCTs (WHI-DM, N = 63,805 and PREDIMED, N = 4,282) and 28 cohort studies, N = 2.5 million.4,23,27,29,31,33-73

##### Total Cancer Incidence

Total cancer incidence was reported in 3 cohort studies and one RCT.23,56,57 Data from the Nurses' Health Study (NHS, N = 71,495 women) and the Health Professionals Follow-up Study (HPFS, N = 41,029 men), both of which had follow-up times of more than 20 years, were reported in one paper. The multivariate adjusted relative risk of any cancer in the highest compared to the lowest quintile of conformity to the Mediterranean diet was 0.94 (95% CI 0.90, 0.98) for men and women combined.56 For women, higher diet conformity was associated with decreased risk of all cancer (RR 0.93, 95% CI 0.88, 0.99) but there was no association for men alone (RR 0.94, 95% CI 0.87, 1.03).56 The third cohort study was conducted in 23 centers in 10 European countries. It enrolled 478,478 men and women and followed them for a median of 8.7 years. Conformity to the Mediterranean diet was assessed using the Mediterranean-diet score, a 9-point score calculated from self- or interviewer-administered food frequency questionnaires.4 Higher conformity to a Mediterranean diet was associated with a significant reduction in cancer incidence (HR 0.96, 95% CI 0.95, 0.97 for a 2-point increment in the Mediterranean-diet score) (Figure 3).57 Pooled results from these 3 studies indicated a significantly lower risk of total cancer incidence in people with higher compared to lower conformity to the Mediterranean diet (RR 0.96, 95% CI 0.95, 0.97).

Figure 3 Cancer Incidence by Cancer Type, Cohort Studies

I^2^ breast = 53%, I^2^ colorectal = 60%

The RCT (WHI-DM, described above) reported similar total cancer incidence in the 2 diet groups (HR 0.97, 95% CI 0.89, 1.05).23

##### Total Cancer Mortality

Total cancer mortality was reported in 13 cohort studies and one RCT.4,23,33,34,38,39,42,43,45,54,55,63,71 Of the 13 cohort studies, 6 were conducted in Europe and 7 in North America. The studies included a total of 534,058 participants. In the one RCT (WHI-DM, described above) total cancer mortality was similar in the 2 diet groups (HR 0.95, 95% CI 0.90, 1.01) (Figure 4).23

Figure 4 Cancer Mortality, Cohort Studies

I^2^ = 77%

Pooled results of the 13 cohort studies are displayed in Figure 4. There was a significant 14% reduction in total cancer mortality in those with the highest level of conformity to the Mediterranean diet compared to those with the lowest level (RR 0.86, 95% CI 0.82, 0.91; I^2^ = 77%).

##### Breast Cancer

Breast cancer incidence was reported in 13 cohort studies and 2 RCTs (WHI-DM and PREDIMED).27,31,35,46,50,51,58,60,62,65,66,69,73,74 Seven were conducted in the United States, 2 in Canada, and 6 in Europe. The 15 studies included more than 800,000 participants. In WHI-DM (described above), breast cancer incidence was similar between the 2 diet groups (HR 0.91, 95% CI 0.83, 1.01)(Figure 5).31 In the PREDIMED trial (described above) breast cancer incidence in 4,152 women followed for 4.8 years was significantly lower compared to the control diet in participants assigned the Mediterranean diet with supplemental EVOO (HR 0.32, 95% CI 0.13, 0.79) but not the Mediterranean diet supplemented with nuts.27

Figure 5 Breast Cancer Incidence from PREDIMED and WHI – DM

Pooled results of the 13 cohort studies are displayed in Figure 3. Breast cancer incidence was similar in those who had the highest level of conformity to the Mediterranean diet and those who had the lowest level of conformity (RR 0.96, 95% CI 0.90, 1.03; I^2^ = 53%).

Breast cancer mortality was reported in one study, a prospective population-based cohort study conducted in Sweden (N = 77,151). It reported no association between conformity to a Mediterranean diet and breast cancer [underlined: mortality] (HR 1.12, 95% CI 0.97, 1.29) (Figure 6).54

Figure 6 Cancer Mortality by Cancer Type, Cohort Studies

##### Colorectal Cancer

Colorectal cancer incidence was reported in 9 cohort studies and one RCT.23,48,53,59,61,68,72 Of the cohort studies, 5 were conducted in Europe, 3 in the US, and one in Japan. These 9 studies included over 1.3 million participants. In the RCT (WHI-DM, described previously) incidence of colorectal cancer and colorectal cancer mortality were similar between the 2 diet groups ([underlined: incidence]: HR 1.08, 95% CI 0.90, 1.29; [underlined: mortality]: HR 1.26, 95% CI 0.85, 1.85).23

Pooled results of the 9 cohort studies are shown in Figure 3. The incidence of colorectal cancer was significantly lower in people with highest conformity to the Mediterranean diet compared to people with the lowest conformity to the Mediterranean diet (RR 0.91, 95% CI 0.84, 0.98; I^2^ = 60%).

A prospective population-based cohort study conducted in Sweden (N = 77,151), reported no association between conformity to a Mediterranean diet and colorectal cancer [underlined: mortality] for men (HR 1.07, 95% CI 0.93, 1.24) or women (HR 0.91, 95% CI 0.77, 1.08) (Figure 6).54

##### Other Site-specific Cancer (Figure 3)

In cohort studies (Figure 3), the incidence of the following cancers was similar between people with high and low levels of conformity to a Mediterranean diet: ovarian (k = 1), pancreatic (k = 2), head and neck (k = 1), lung (k = 1), bladder (k = 1), prostate (k = 3), and gastric cancer (k = 2).29,36,37,40,41,44,47,49,52,67,75 In an RCT (WHI-DM, described previously) incidence of ovarian, endometrial, and skin cancers were similar between the 2 diet groups.29,31

Two studies reported cancer site-specific mortality (Figure 6). In addition to the findings for breast and colorectal cancer mortality, the prospective population-based cohort study conducted in Sweden (N = 77,151), reported no association between conformity to a Mediterranean diet and stomach, prostate, or respiratory cancer mortality.54 The authors did find an association between Mediterranean diet score and lower pancreatic cancer mortality but it was only significant in men (HR 0.82, 95% CI 0.68, 0.99).54 A prospective US population-based cohort study of 293,464 men followed for an average of 8.9 years reported no association between conformity to a Mediterranean diet and incidence of fatal prostate cancer (HR 0.80, 95% CI 0.59, 1.10).52

#### Cognitive Functioning

The effect of a Mediterranean diet on prevention of cognitive decline was reported in 2 RCTs and 14 cohort studies. A RCT conducted in Hong Kong enrolled “old age hostel” residents 75 years of age and older.24 “Brain preservation” diet meals (fruits, vegetables, fish, reduced salt intake, and less refined sugar) were provided to the residents in the intervention group. The mean age of the 429 participants was 83 years. At baseline, 59% of the intervention group and 66% of the control group had “questionable dementia” (defined as a Clinical Dementia Rating [CDR] score of 0.5). At 33 months follow-up, data were available for 79% of the intervention group and 80% of the control group. The intervention and control groups were similar in the proportion of patients who were classified as demented (14% intervention, 17% control; RR 0.81, 95% CI 0.49, 1.35) or with cognitive decline (a worsening of the CDR score) (22% intervention, 27% control, RR 0.82, 95% CI 0.56, 1.19) (Figures 7 and 8).24

Figure 7 Mild Cognitive Impairment (PREDIMED) or Cognitive Decline (Kwok)*

* Cognitive decline as defined by an increase in Clinical Dementia Rating Scale score

Figure 8 Dementia

The second RCT was the PREDIMED study. Two of the study sites, Barcelona and Navarra, evaluated the effect of diet on incidence of mild cognitive impairment (MCI) and reported their results independently (Figure 7).25,28 The Barcelona site, which enrolled 334 people followed for a median of about 4 years, reported similar Mini-Mental State Examination (MMSE) scores and risk of MCI for the intervention and control groups (Figure 7).28 The Navarra site, which enrolled 522 people followed for a mean of 6.5 years, reported that the risk of MCI was significantly lower in the Mediterranean diet group (RR 0.54, 95% CI 0.34, 0.88) (Figure 7).25 The Navarra site also reported a significantly lower incidence of dementia in the intervention groups compared to the control group (RR 0.36, 95% CI 0.19, 0.67) (Figure 8).25

Among the 14 cohort studies, 8 were from the US, 3 from Europe, and 3 from Australia.76-91 Enrollments ranged from 527 to 16,058 and mean ages at enrollment (reported in 12 of the studies) ranged from 52 to 82. One study used 24-hour dietary records to compute a Mediterranean diet score that ranged from 0 to 9 and a Mediterranean-Style Dietary Pattern score that ranged from 0 to 100%.80 The remaining studies used food frequency questionnaires to compute a Mediterranean-diet score, most commonly the instrument validated by Trichopoulou (2003), with values ranging from 0 to 9.^4^ Follow-up periods ranged from 18 months to 28 years. The single most commonly used cognitive assessment tool was the mini-mental status exam (MMSE), although most studies used a battery of 4 to 18 tests.

Among these 14 cohort studies, only 7 found a significant association between higher conformity to a Mediterranean diet and improved cognitive outcomes (see bulleted list below). Studies presenting data in a way that allowed for determination of risk ratios are presented in Figure 9.

- An Australian study reported a significant correlation between baseline Mediterranean diet score and improvement in MMSE at 18 months, although tests of memory, verbal learning, and verbal fluency did not improve.78 A study from France reported similar results finding higher diet conformity associated with fewer MMSE errors over a 5-year follow-up but no association with other cognitive tests or incident dementia.77
- Two studies from the US reported slower rates of cognitive decline (assessed with a battery of tests) were associated with higher Mediterranean diet conformity over mean follow-up periods of 4 years and 7.6 years.89,90 Another US study reported a similar outcome for MMSE scores over a mean follow-up of 10.6 years.91
- A US study found a significant association between the highest tertile of Mediterranean-diet score and development of AD over a 4 year (mean) follow-up.88 The significant association was maintained when the model was adjusted for all vascular variables.86 In further analyses of the same cohort, a significant association between increased Mediterranean diet conformity and decreased risk of MCI was observed when diet was expressed as a continuous variable but the association was not significant when diet was expressed categorically (tertiles).87 Another analysis found lower risk of AD in participants with high Mediterranean diet conformity and high levels of physical activity relative to those with low conformity and low activity.85
- A study from the US found no association between Mediterranean diet and decline in modified MMSE scores in the overall population although the association was significant in the African-American participants.92
- Five studies (2 from the US, and one each from Australia, France, and Greece) reported that diet conformity was not significantly associated with cognitive scores.79-81,83,84
- Two studies (one from the US and one from Australia) reported that diet conformity was not significantly associated with development of mild cognitive disorder (any), mild cognitive impairment, or dementia.76,82

Figure 9 Cognitive Outcomes for Observational Studies

#### Rheumatoid Arthritis

Rheumatoid arthritis was an outcome of interest in one paper. They reported results from the NHS and NHS-II, which together included 174,638 female registered nurses followed for over 20 years. Analysis of pooled data found similar risk of developing rheumatoid arthritis in women who scored in the highest and lowest quartiles of the aMED score (HR 0.98, 95% CI 0.80, 1.20).93

#### Diet-related Adverse Events

Participants in the PREDIMED study reported that they experienced no diet-related adverse effects.

## KEY QUESTION 1A DO THE EFFECTS VARY BY GENDER, AGE, OR BMI?

### Gender

No RCTs reported outcomes stratified by gender. Seven cohort studies reported all cancer incidence and colorectal, head and neck, and pancreatic cancer incidence. Six cohort studies reported all cancer mortality separately in men and women (Table 2).33,34,38-40,48,54,56,57,59,61,67,68,72

Table 2 Effect of Greater Diet Conformity on Outcomes by Gender, Age, and BMI in Cohort Studies

Outcomes and Studies | Gender | Age | BMI
All Cancer Incidence
NHS/HPFS56 | Significantly lower in women not men
EPIC57 | Significantly lower in women and men
Bladder Cancer Incidence
EPIC75 | | Similar in all age groups | Similar in all BMI groups
Breast Cancer Incidence
SMSC73 | | Similar in all age groups
BWHS60 | | | Significantly lower with BMI < 25 only
Colorectal Cancer Incidence
NIH-AARP61 | Significantly lower in men not women
Kyro 2013^48^ | Significantly lower in women not men
NLCS72 | Similar in women and men
JPHC68 | Similar in women and men
NHS/HPFS59 | Similar in women and men
Head and Neck Cancer Incidence
NIH-AARP40 | Significantly lower in women not men
Pancreatic Cancer Incidence
NHS/HPFS67 | Significantly higher in men not women
All Cancer Mortality
MEC34 | Significantly lower in women and men
NHS/HPFS39 | Similar in women and men
NIH-AARP38 | Significantly lower in women and men
Tognon 2012^54^ | Significantly lower in men not women
SNCG33 | Significantly lower in men not women
SWLH63 | | Similar in all age groups
WHI-OS42 | | | Significantly lower with BMI <30 only
Cognitive Function
MAP90 | Significantly better in women and men | Significantly better in all age groups
SU.VI.MAX80 | Similar in women and men

Two cohort studies reported cognitive performance by gender (Table 2).80,90

### Age

The WHI-DM reported risk of composite coronary heart disease and T2DM by age and found no significant interaction between age and risk for either (P = .58 and P = .66, respectively).30,32

Two RCTs reported cancer incidence stratified by age groups. The WHI-DM RCT reported total invasive cancer, invasive ovarian cancer, colorectal cancer, non-melanoma skin cancer, and melanoma incidence by diet group for 3 age strata: 50-59 years, 60-69 years, and 70 years and older.23,29,31 There were no significant interactions between age group and intervention group. The PREDIMED trial reported a post-hoc subgroup analysis of breast cancer incidence in women over and under the age of 67. Breast cancer incidence was significantly reduced in women who were 67 years old or younger (HR 0.16, 95% CI 0.05, 0.50) but not in women over the age of 67 (HR 0.92, 95% CI 0.34, 2.47).27 However, a test for interaction was not reported.

Two cohort studies reported cancer incidence by age groups and one reported cancer mortality by age (Table 2).63,72,75

One cohort study reported cognitive outcomes by age (Table 2).90

### BMI

The WHI-DM reported risk of composite coronary heart disease and T2DM by BMI and found no significant interaction between BMI and risk for either (P = .07 and P = .74, respectively).30,32

Two RCTs reported outcomes by BMI. In WHI-DM there were no differences in incidence of total invasive, invasive ovarian, colorectal, or non-melanoma skin cancers by BMI category.23,29,31 The PREDIMED trial found significantly reduced breast cancer incidence in women with a BMI less than 30 (HR 0.29, 95% CI 0.11, 0.83) but not in those with a BMI of 30 or greater (HR 0.57, 95% CI 0.22, 1.49). However, a test for interaction was not reported.27

Two cohort studies reported cancer incidence by BMI groups (Table 2).51,60 One cohort study (WHI-OS) reported all cancer mortality in different BMI groups (Table 2).42

### Summary of Findings for Key Questions 1 and 1A

There is evidence from one RCT that the Mediterranean diet significantly decreases risk of major cardiovascular events, development of T2DM, and incidence of breast cancer.7,26,27 Cohort studies suggest that the Mediterranean diet may be associated with decreased incidence of, and mortality from, cancer. The data on cognitive impairment and the available subgroup analyses by age, gender, and BMI are limited and showed mixed results.

### Strength of Evidence for Key Questions 1 and 1A

We assessed strength of evidence for all-cause mortality, cancer incidence, and cognitive functioning. The strength of evidence was low for all outcomes evaluated (Table 3).

Table 3 Strength of Evidence

Outcome | Strength of evidence | | Direction | Study design; # studies (N) | Summary/Rationale^a^
Key Question 1: Primary Prevention Studies
All-cause Mortality | Low | | Similar | 3 RCTs PREDIMED (7,447) WHI-DM (48,835) Kwok 2012 (429) | Incidence of all-cause mortality was similar between the Mediterranean-like diet and the control diet groups in the 2 larger studies (PREDIMED-combined diets HR 0.89 [95% CI 0.71, 1.12]; WHI HR 0.98 [95% CI 0.91, 1.07]). The trials were not pooled due to large dissimilarity of the study diets. Overall risk of bias is low. Consistency is unknown and there was imprecision (PREDIMED).
All Cancers Incidence | Low | | RCT Similar Observational Lowered risk | 1 RCT WHI-DM (48,835) 3 Observational (591,002) | In WHI, all cancer incidence was similar between the Mediterranean-like diet and the control diet groups (HR 0.97 [95% CI 0.89, 1.05]). Three large cohort studies reported highest conformity to a Mediterranean diet was associated with a reduction in total cancer incidence compared with lowest conformity (reference group) (pooled HR 0.96 [95% CI 0.95, 0.97]). There is inconsistency between WHI and the cohort studies, and overall risk of bias is medium.
Breast Cancer Incidence | Low | | RCT Mixed Observational Similar | 2 RCTs WHI-DM (48,835) PREDIMED (4,152) 13 Observational (range 3,320 to 355,062) | In PREDIMED, breast cancer incidence was lower in the combined Mediterranean diet groups compared to control (HR 0.43 [95% CI 0.21, 0.88]). In WHI, breast cancer incidence was similar between the Mediterranean-like diet and the control diet groups (HR 0.91 [95% CI 0.83, 1.01]). The trials were not pooled due to large dissimilarity of the study diets; consistency is unknown. The cohort studies found breast cancer incidence was similar between the highest and lowest conformity groups (RR 0.96 [95% 0.90, 1.03]). Overall risk of bias is medium.
Colorectal Cancer Incidence | Low | | RCT Similar Observational Lowered risk | 1 RCT WHI-DM (48,835) 9 Observational (range 19,133 to 397,641) | In WHI, colorectal cancer incidence was similar between the Mediterranean-like diet and the control diet groups (RR 1.08 [95% CI 0.90, 1.29]). In the cohort studies, highest conformity to a Mediterranean diet was associated with a reduction in colorectal cancer incidence compared with the lowest conformity (RR 0.91 [95% 0.84, 0.98]) with moderate heterogeneity between studies (I^2^ = 60%). There is inconsistency between WHI and the cohort studies, and overall risk of bias is medium.
Cognitive Functioning | Low | Mixed | | 2 RCTs PREDIMED (334 and 522) Kwok24 (429) 14 Observational (range 527 to 16,058) | A sub-study of PREDIMED involving cognitively healthy volunteers (n = 334) reported incidence of MCI was similar between the Mediterranean diet and the control diet groups. A sub-study of PREDIMED of patients with high vascular risk (n = 522) reported risk of MCI and dementia was lower in the Mediterranean diet group compared with the control diet group. An Asian trial of older nursing home residents (n = 429) found the proportions of patients classified as demented or with cognitive decline was similar between the Mediterranean-like diets and the control diet groups. The trials were not pooled due to the large dissimilarity of the study diets and populations, resulting in unknown consistency. Overall risk of bias is moderate. The results from the observational studies were mixed. Three studies analyzing Mediterranean diet as a continuous score reported higher conformity to a Mediterranean diet slowed rates of cognitive decline; 4 did not. Six cohort studies analyzing Mediterranean diet as a categorical variable reported no association with levels of diet conformity and cognitive outcomes; 3 reported mixed results across different subgroups or analyses. Overall risk of bias is medium.
Key Question 2: Secondary Prevention Studies
All-cause Mortality | Insufficient | Similar | | 3 RCTs (2,277) | Incidence of all-cause mortality was similar between the Mediterranean-like diets and the control diet groups (RR 0.95 [95% CI 0.53, 1.69]; I^2^ = 51%). There is large imprecision and inconsistency, and overall risk of bias is medium.

RCT = randomized controlled trial; PREDIMED = Prevención con Dieta Mediterránea; WHI = Women's Health Initiative; HR = hazard ratio; RR = risk ratio; MCI = mild cognitive impairment

a Strength of Evidence Definitions22

- Precision: Degree of certainty surrounding an effect estimate; in meta-analysis, the confidence interval around the summary effect size
- Consistency: Degree to which reported effect sizes appear to have the same direction of effect
- Directness: Whether the evidence links the interventions directly to health outcomes
- Risk of bias: Degree to which includes studies have a high likelihood of protection against bias; 2 main elements are study design and aggregate quality of the studies

## KEY QUESTION 2 Compared to other diets, is the Mediterranean diet associated with fewer adverse outcomes (including death) or less disease progression in people who already have diabetes, cardiovascular disease, cancer, hypertension, cognitive impairment, rheumatoid arthritis, or kidney disease?

### Overview of Studies (Table 4 and Appendix C, Table 5)

Table 4 Summary of Included Studies - Key Question 2

Characteristic | Mean (range) Unless Otherwise Noted | Number of Studies Reporting
Total number of patients evaluated | 19,972 (51 to 4,538) | 15
Randomized controlled trials, total number of patients | 5,865 (51 to 3,114) | 8
Cohort studies, total number of patients | 14,107 (482 to 4,538) | 7
Secondary prevention of cancer, total number of patients | 13,625 (926 to 4,538) | 6
Secondary prevention of cardiovascular disease, total number of patients | 5,684 (101 to 3,114) | 6
Secondary prevention of cognitive impairment, total number of patients | 482 | 1
Secondary prevention of rheumatoid arthritis, total number of patients | 181 (51 to 130) | 2
Age of subjects, years | 61.8 (54 to 78) | 9
Gender, % male patients in mixed gender studies | 64.2% (20 to 90) | 5
Mixed Gender studies, total number of patients | 4,112 (51 to 1,009) | 8
Male only studies, total number of patients | 8,578 (926 to 4,538) | 3
Female only studies, total number of patients | 7,282 (130 to 2,619) | 4
Body Mass Index | 26.8 (25.4 to 28) | 6
Location - USA/Canada, total number of patients | 11,686 (101 to 4,538) | 7
Location - Europe, total number of patients | 6,422 (51 to 3,114) | 5
Location - Asia/Australia, total number of patients | 1,864 (406 to 1,000) | 3

We identified a total of 19 articles reporting results from 15 studies (Table 4). Eight of the studies were randomized controlled trials and 7 were cohort studies. Six studies were conducted in patients with cancer, 6 in patients with cardiovascular disease, one in patients with cognitive impairment, and 2 in patients with rheumatoid arthritis. Seven of the 15 studies were done in the United States, 5 in Europe, and 3 in Asia. The total number of participants was 19,972 and the mean sample size was 1,331. The mean age of participants was 61.8 years (k = 9 reporting) and the mean BMI was 26.8 (k = 6). Of studies that included both men and women, the mean percentage of men was 64.2% (k = 5). The dietary interventions used in the RCTs are described in Table 5. The cohort studies used a variety of scales to rate each individual's degree of conformity to the Mediterranean diet (see Methods section). No studies reported kidney disease or hypertension.

Table 5 Dietary Interventions Used in Trials

RCT Author , Year | Intervention Diet | Control Diet
Burr 2003^94^ | 3 components (fruits/vegetables, grains/cereals, and low meat/fish) | - Fish; - Fruit/vegetables and grains/cereals; - ‘Sensible eating’ non-specific advice that did not include the intervention
Lyon Heart Study6,95-97 | 4 components (fat ratio, fruits/vegetables, grains/cereals, and low meat/fish) | Did not receive dietary information from the investigators
Singh 2002^98^ | 4 components (fat ratio, fruits/vegetables, legumes, and grains/cereals) | National Cholesterol Education Program Step I Prudent Diet (low total and saturated fat, and low cholesterol)
Singh 1992^99^ | 2 components (fruits/vegetables, low meat/fish) | Prudent diet reflecting the recommendations of the American Heart Association (low meat, eggs, and hydrogenated oil/butter; replaced by meat substitutes and nut oils)
Singh 1991^100^ | 5 components (fat ratio, fruit/vegetables, legumes, grains/cereals, and low meat/fish) | Usual care
Tuttle 2008^8^ | 7 components (fat ratio, fruit/vegetables, legumes, grains/cereals, red wine, dairy, and low meat/fish) | Low-fat diet, the American Heart Associate Step II diet (low saturated fat and cholesterol, fruits/vegetables, and grains/cereals)
McKellar 2007^101^ | 3 components (fat ratio, fruit/vegetables, and legumes) | Received readily available written information on healthy eating
Skoldstam 2003^102^ | 3 components (fat ratio, fruit/vegetables, and dairy) | Usual diet

### Outcomes (Appendix C, Tables 6 – 11)

#### Cardiovascular Disease and All-cause Mortality

Six RCTs (N = 5,684) reported outcomes in participants with pre-existing cardiovascular disease. The mean sample size was 947. One study was set in the United States, 2 in Europe, and 3 in Asia. The outcomes reported in these studies included all-cause mortality (k = 6), cardiovascular mortality (k = 5), diet-related adverse events (k = 2), new myocardial infarction (k = 5), new stroke (k = 4), new revascularization procedure (k = 3), and development of heart failure (k = 4). Three of the RCTs may contain fraudulent data so we performed our analyses both including and excluding these studies.98-100,103

The other 3 RCTs were:

- The Lyon Heart Study which enrolled 605 people after a first myocardial infarction, randomized them to either a 3-component Mediterranean diet group or a no-advice group, and followed them for an average of 2.3 years.95
- A Welsh trial which randomized 3,114 men with a history of angina to 4 diet groups (1. oily fish; 2. fruit, oats, and fiber; 3. combination of 1 and 2; and 4. non-specific advice). Group 3 met our definition of a Mediterranean diet. This trial was interrupted by funding problems. Many of the analyses were performed not by group but by specific dietary components (eg, fish advice, fruit advice).94
- A trial from Spokane, Washington that enrolled 101 patients within 6 weeks of a first myocardial infarction and randomized them to either a “Mediterranean-style diet” (low fat that emphasized increased consumption of fruits and vegetables, whole grains, cold-water fish, and oils from olives, canola, and soy beans) or a low-fat diet (that emphasized fruits and vegetables and whole grains) and followed them for an average of 4 years.8

##### All-cause Mortality

All 6 of the cardiovascular RCTs reported all-cause mortality. Two of these RCTs reported significantly decreased all-cause mortality in the participants assigned to the Mediterranean compared to the control diet (RR 0.44, 95% CI 0.21, 0.94 and RR 0.55, 95% CI 0.34, 0.75) respectively).6,97,99 Four studies found similar mortality in the Mediterranean and control diet groups.8,94,98,100

Pooled results from the 6 studies showed that all-cause mortality was similar in the Mediterranean diet and the control diet groups (RR 0.85, 95% CI 0.59, 1.21; I^2^ = 57%).6,8,94,97-100 The analysis conducted without the questionable data also showed no evidence of reduction in all-cause mortality (RR 0.95, 95% CI 0.53, 1.69; I^2^ = 51%).6,8,94,97

##### Cardiovascular Mortality

Five RCTs reported cardiovascular mortality. Two studies found decreased cardiovascular mortality in participants assigned a Mediterranean diet compared to controls (RR 0.35, 95% CI 0.15, 0.83 and RR 0.58, 95% CI 0.34, 0.83, respectively).6,97,99 The other 3 studies found that cardiovascular mortality was similar in both diet groups.8,94,98

Pooled data from all 5 RCTs show that cardiovascular mortality was similar in groups assigned a Mediterranean and control diet (RR 0.69, 95% CI 0.44, 1.08; I^2^ = 67%).6,8,94,97-99 This result was essentially unchanged when the analysis was conducted without the questionable data (RR 0.68, 95% CI 0.18, 2.47; I^2^ = 87%).6,8,94,97

##### Myocardial Infarction

New myocardial infarction was reported as an outcome in 5 RCTs. Two of the 5 studies reported significantly decreased rates of MI in participants assigned to the Mediterranean diet group.98,99 A third study found similar rates of MI for both groups.8 The other 2 studies reported fewer MIs in the intervention group than in the control group but the statistical significance of these differences was not reported.6,100

We were able to pool data from 4 of the RCTs.6,8,98,99 The pooled data show that randomization to a Mediterranean diet significantly decreased risk of a new MI (RR 0.56, 95% CI 0.44, 0.72; I^2^ = 0%). This finding remained essentially the same when the analysis was conducted without the questionable data (RR 0.32, 95% CI 0.15, 0.67; I^2^ = 0%).6,8

##### Stroke

Four RCTs reported new stroke. Two found similar rates in both diet groups.8,98 The other 2 studies reported fewer strokes in the intervention group than control but did not report the statistical significance.96,100

Analysis of the 3 studies that could be pooled shows that participants assigned a Mediterranean diet had similar incidence of new stroke as those assigned a control diet (RR 0.66, 95% CI 0.19, 2.30; I^2^ = 31%).8,96,98 This finding was not qualitatively different when the questionable data were removed (RR 0.76, 95% CI 0.04, 14.51; I^2^ = 61%).8,96

##### Other Outcomes

Three RCTs reported incidence of revascularization procedures.8,95,96,98 The pooled data show similar incidence in the Mediterranean diet and the control diet groups (RR 0.75, 95% CI 0.42, 1.35). This finding was the same when the questionable data were excluded (RR 0.91, 95% CI 0.54, 1.53).8,95,96

Four RCTs reported development of heart failure.6,95,96,98,100 One of the studies, whose data integrity has been questioned, found that participants assigned a Mediterranean diet developed heart failure significantly less often than participants assigned a control diet although the relative risk was not reported.98 Another study from the same group reported that 2 patients in the Mediterranean diet group and 2 patients in the control diet group developed heart failure.100 A US study reported no heart failure in either diet group.8 The Lyon Heart study reported 6 cases of heart failure in the Mediterranean diet group and 11 in the control group.6,96

#### Cancer

Six cohort studies reported outcomes in people with cancer at baseline (N = 13,625). Three of these reported breast cancer outcomes, 2 colon cancer, and 2 prostate cancer.41,104-110 Five studies were conducted in the United States and one in Europe. The average sample size was 2,271 and the mean age of participants was 64.4 years (k = 3).

##### Breast Cancer (k = 3)

Both a German study that followed 2,522 post-menopausal breast cancer patients for a median of 5.5 years, and a US study of 1,901 women with early stage breast cancer followed for an average of 3.2 years found similar rates of breast cancer recurrence and mortality across quartiles of conformity to the Mediterranean diet (P for trends >0.05) (Figure 10).107,109 The NHS, an American study following nurses for more than 6 years, found similar rates of breast cancer mortality across quantiles of an aMED score and, in a sub-study, conformity to a prudent pattern.105,106

Figure 10 Cancer-specific Mortality by Cancer Typea

^a^ Sample sizes based on numbers in highest and lowest quantiles (the comparison groups), if provided; otherwise sample size is for entire cohort

##### Colon Cancer (k = 2)

A US study of 1,009 patients with stage III colon cancer followed for an average of 5.3 years found similar rates of colon cancer recurrence across quintiles of conformity to the Mediterranean diet (termed a “prudent” diet) (HR 1.13, 95% CI 0.77, 1.67).108 A second US study (NHS) of 1,201 women with stage I-III colon cancer followed for a median of 11.2 years evaluated colon cancer-specific mortality and found no association with aMED score or prudent pattern (Figure 10).104

##### Prostate Cancer (k = 2)

A US study, the Health Professionals Follow-up Study (HPFS), followed 4,538 men with prostate cancer for an average of 9 years and found similar incidence of prostate cancer-specific mortality comparing highest to lowest conformity to a Mediterranean diet (HR 1.01, 95% CI 0.74, 1.37) (Figure 10).41 Another US study, the Physicians' Health Study (PHS), followed men for 9.9 years and also found similar incidence of prostate cancer specific mortality in participants in the highest and lowest quantiles of a prudent dietary pattern (HR 0.46, 95% CI 0.17, 1.24).110

#### Cognitive Impairment

One cohort study of 482 Medicare beneficiaries in New York with mild cognitive impairment reported progression to Alzheimer's Disease.87 Mean age at enrollment was 78 years and 32% of participants were male. Mean follow-up was 4.3 years. When conformity to a Mediterranean diet was analyzed as a continuous variable, the hazard ratio (per unit of Mediterranean-diet score) for development of AD was not significant (0.89, 95% CI 0.78, 1.02). When conformity to a Mediterranean diet was analyzed by tertiles with the lowest tertile as the reference group, the hazard ratios were significant for both the middle and highest tertiles, indicating that greater conformity to a Mediterranean diet was associated with a lower risk of developing AD. For the highest tertile, the hazard ratio was 0.52 (95% CI 0.30, 0.91).

#### Rheumatoid Arthritis

One RCT from Sweden and one CCT from the UK enrolled patients with rheumatoid arthritis.101,102 The RCT included 51 patients with clinically stable disease of at least 2 years duration.102 Intervention group patients received dietary instructions and some food supplied at no cost. The control group followed a usual diet. After a 3-week outpatient rehabilitation program (meals provided according to group assignment), participants prepared their own meals for the next 9 weeks. Mean age was 58 years, 20% were male, and mean disease duration was 13.6 years (significantly longer in the intervention group: 17 years vs 10 years). There were significant improvements at 12 weeks in the Mediterranean diet group compared to the control group on a global pain score, the 28 joint disease activity score, and the health assessment questionnaire.102

The CCT enrolled 130 women age 30 to 70 years from areas of “social deprivation.” Participants received either instruction on the Mediterranean diet or readily available information on healthy eating. Mean age of the participants was 54 years; mean disease duration was 9.4 years. At 6 months, mean global pain scores were significantly lower in the Mediterranean diet group compared to the control group. Mean scores on the Health Assessment Questionnaire were significantly better in the Mediterranean diet group at 3 months but not 6 months. Joint disease activity scores were similar in both groups at 3 and 6 months.101

#### Diet-related Adverse Events

Four studies reported adverse events related to the diet. One found no side effects8 while the other 3 reported minor digestive problems such as diarrhea, dyspepsia, and mild belching in a couple of patients assigned to the intervention diet.8,95,99,102

## KEY QUESTION 2A Do the effects vary by gender, age, or BMI?

The reported data did not allow for subgroup analysis by age, gender, or BMI.

### Summary of Findings for Key Question 2

Randomization to a Mediterranean diet significantly reduced myocardial infarction but had no significant effects on cardiovascular mortality, stroke, revascularization procedures, or congestive heart failure. There is no evidence that a Mediterranean diet reduces incidence of recurrent breast or colon cancer or mortality associated with breast, colon, or prostate cancer. There is limited, mixed data on the effects of the Mediterranean diet on progression of cognitive impairment and rheumatoid arthritis.

### Strength of Evidence for Key Question 2

We assessed strength of evidence for all-cause mortality only and it was rated as insufficient (Table 3).

## KEY QUESTION 3 What is the observed adherence to the Mediterranean diet in studies conducted in the United States or Canada?

Two RCTs, conducted in the United States, reported data on adherence (Appendix C, Tables 12 and 13). The WHI-DM, described above in Key Question 1, reported significant changes (all P<0.001) at year 3 in the intervention compared to the control group in consumption of red meat (20% reduction), grains (18% increase), and vegetables and fruit (47% increase).23

The second study was a 4-site population-based multicenter trial that enrolled 810 adults with mildly elevated blood pressure.111 About a third of the participants were African-American and all were recruited from the community. Subjects were randomized to one of 3 groups: general advice on diet, physical activity, and weight loss delivered in 2 30-minute sessions (Group A); behavioral interventions including group and individual counseling sessions designed to encourage weight loss and increase physical activity (Group B); and Group C, which in addition to the Group B interventions received specific advice on increased consumption of fruits and vegetables and low-fat dairy products and reduced consumption of total and saturated fat. At 18 months of follow-up, there was a significant increase of 2.6 (95% CI 2.2, 3.2) servings per day of fruits and vegetables in group C compared to either of the other 2 groups.111