# REFERENCES

1 Keys A. Diet and the epidemiology of coronary heart disease. JAMA. 1957;164(17):1912-1919.
2 Fundacion Dieta Mediterranea. What's the Mediterranean Diet?. http://dietamediterranea.com/en/. October 5, 2015. 2015.
3 Buckland G, Gonzalez CA, Agudo A, et al. Adherence to the Mediterranean diet and risk of coronary heart disease in the Spanish EPIC Cohort Study. Am J Epidemiol. 2009;170(12):1518-1529. [pmid: 19903723].
4 Trichopoulou A, Costacou T, Bamia C, Trichopoulos D. Adherence to a Mediterranean diet and survival in a Greek population. New Engl J Med. 2003;348(26):2599-2608. [pmid: 12826634].
5 Fung TT, Rexrode KM, Mantzoros CS, Manson JE, Willett WC, Hu FB. Mediterranean diet and incidence of and mortality from coronary heart disease and stroke in women. Circulation. 2009;119(8):1093-1100. [pmid: 19221219].
6 de Lorgeril M, Salen P, Martin JL, Monjaud I, Delaye J, Mamelle N. Mediterranean diet, traditional risk factors, and the rate of cardiovascular complications after myocardial infarction: final report of the Lyon Diet Heart Study. Circulation. 1999;99(6):779-785. [pmid: 9989963].
7 Estruch R, Ros E, Salas-Salvado J, et al. Primary prevention of cardiovascular disease with a Mediterranean diet. New Engl J Med. 2013;368(14):1279-1290. [pmid: 23432189].
8 Tuttle KR, Shuler LA, Packard DP, et al. Comparison of low-fat versus Mediterranean-style dietary intervention after first myocardial infarction (from The Heart Institute of Spokane Diet Intervention and Evaluation Trial). Am J Cardiol. 2008;101(11):1523-1530. [pmid: 18489927].
9 Esposito K, Chiodini P, Maiorino MI, Bellastella G, Panagiotakos D, Giugliano D. Which diet for prevention of type 2 diabetes? A meta-analysis of prospective studies. Endocrine. 2014;47(1):107-116. [pmid: 24744219].
10 Koloverou E, Esposito K, Giugliano D, Panagiotakos D. The effect of Mediterranean diet on the development of type 2 diabetes mellitus: a meta-analysis of 10 prospective studies and 136,846 participants. Metab Clin Exp. 2014;63(7):903-911. [pmid: 24931280].
11 Lourida I, Soni M, Thompson-Coon J, et al. Mediterranean diet, cognitive function, and dementia: a systematic review. Epidemiology. 2013;24(4):479-489. [pmid: 23680940].
12 Maderuelo-Fernandez JA, Recio-Rodriguez JI, Patino-Alonso MC, et al. Effectiveness of interventions applicable to primary health care settings to promote Mediterranean diet or healthy eating adherence in adults: A systematic review. Prev Med. Suppl. 2015;76:S39-55. [pmid: 25524613].
13 Martinez-Gonzalez MA, Bes-Rastrollo M. Dietary patterns, Mediterranean diet, and cardiovascular disease. Curr Opin Lipidol. 2014;25(1):20-26. [pmid: 24370845].
14 Nordmann AJ, Suter-Zimmermann K, Bucher HC, et al. Meta-analysis comparing Mediterranean to low-fat diets for modification of cardiovascular risk factors. Am J Med. 2011;124(9):841-851 e842. [pmid: 21854893].
15 Opie RS, Ralston RA, Walker KZ. Adherence to a Mediterranean-style diet can slow the rate of cognitive decline and decrease the risk of dementia: a systematic review. Nutr Diet. 2013;70(3):206-217.
16 Psaltopoulou T, Sergentanis TN, Panagiotakos DB, Sergentanis IN, Kosti R, Scarmeas N. Mediterranean diet, stroke, cognitive impairment, and depression: A meta-analysis. Ann Neurol. 2013;74(4):580-591. [pmid: 23720230].
17 Rees K, Hartley L, Flowers N, et al. “Mediterannean” dietary pattern for the primary prevention of cardiovascular disease. Cochrane Database Syst Rev. 2014;(8).
18 Sofi F, Macchi C, Abbate R, Gensini GF, Casini A. Mediterranean diet and health status: an updated meta-analysis and a proposal for a literature-based adherence score. Public Health Nutr. 2014;17(12):2769-2782. [pmid: 24476641].
19 Schwingshackl L, Hoffmann G. Adherence to Mediterranean diet and risk of cancer: a systematic review and meta-analysis of observational studies. Int J Cancer. 2014;135(8):1884-1897. [pmid: 24599882].
20 Higgins H, Green S. Cochrane Handbook for Systematic Reviews of Interventions Version 5.1.0. The Cochrane Collaboration. 2011.
21 Higgins JP, Thompson SG, Deeks JJ, Altman DG. Measuring inconsistency in meta-analyses. BMJ. 2003;327(7414):557-560. [pmid: 12958120].
22 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--agency for healthcare research and quality and the effective health-care program. J Clin Epidemiol. 2010;63(5):513-523. [pmid: 19595577].
23 Beresford SA, Johnson KC, Ritenbaugh C, et al. Low-fat dietary pattern and risk of colorectal cancer: the Women's Health Initiative Randomized Controlled Dietary Modification Trial. JAMA. 2006;295(6):643-654. [pmid: 16467233].
24 Kwok TC, Lam LC, Sea MM, Goggins W, Woo J. A randomized controlled trial of dietetic interventions to prevent cognitive decline in old age hostel residents. Eur J Clin Nutr. 2012;66(10):1135-1140. [pmid: 22948946].
25 Martinez-Lapiscina EH, Clavero P, Toledo E, et al. Mediterranean diet improves cognition: the PREDIMED-NAVARRA randomised trial. J Neurol Neurosurg Psychiatry. 2013;84(12):1318-1325. [pmid: 23670794].
26 Salas-Salvado J, Bullo M, Estruch R, et al. Prevention of diabetes with Mediterranean diets: a subgroup analysis of a randomized trial. Ann Intern Med. 2014;160(1):1-10. [pmid: 24573661].
27 Toledo E, Salas-Salvado J, Donat-Vargas C, et al. Mediterranean diet and invasive breast cancer risk among women at high cardiovascular risk in the PREDIMED trial: a randomized clinical trial. JAMA Intern Med. 2015;175:1752-1760. [pmid: 26365989].
28 Valls-Pedret C, Sala-Vila A, Serra-Mir M, et al. Mediterranean diet and age-related cognitive decline: a randomized clinical trial. JAMA Intern Med. 2015;175(7):1094-1103. [pmid: 25961184].
29 Gamba CS, Stefanick ML, Shikany JM, et al. Low-fat diet and skin cancer risk: the Women's Health Initiative Randomized Controlled Dietary Modification Trial. Cancer Epidemiol Biomark Prev. 2013;22(9):1509-1519.
30 Tinker LF, Bonds DE, Margolis KL, et al. Low-fat dietary pattern and risk of treated diabetes mellitus in postmenopausal women: the Women's Health Initiative Randomized Controlled Dietary Modification Ttrial. Arch Intern Med. 2008;168(14):1500-1511. [pmid: 18663162].
31 Prentice RL, Thomson CA, Caan B, et al. Low-fat dietary pattern and cancer incidence in the Women's Health Initiative Dietary Modification randomized controlled trial. J Natl Cancer Inst. 2007;99(20):1534-1543. [pmid: 17925539].
32 Howard BV, Van Horn L, Hsia J, et al. Low-fat dietary pattern and risk of cardiovascular disease: the Women's Health Initiative Randomized Controlled Dietary Modification Trial. JAMA. 2006;295(6):655-666. [pmid: 16467234].
33 Vormund K, Braun J, Rohrmann S, Bopp M, Ballmer P, Faeh D. Mediterranean diet and mortality in Switzerland: an alpine paradox?. Eur J Nutr. 2015;54(1):139-148. [pmid: 24710740].
34 Harmon BE, Boushey CJ, Shvetsov YB, et al. Associations of key diet-quality indexes with mortality in the Multiethnic Cohort: the Dietary Patterns Methods Project. Am J Clin Nutr. 2015;101(3):587-597. [pmid: 25733644].
35 Catsburg C, Kim RS, Kirsh VA, Soskolne CL, Kreiger N, Rohan TE. Dietary patterns and breast cancer risk: a study in 2 cohorts. Am J Clin Nutr. 2015;101(4):817-823. [pmid: 25833979].
36 Buckland G, Travier N, Huerta JM, et al. Healthy lifestyle index and risk of gastric adenocarcinoma in the EPIC cohort study. Int J Cancer. 2015;137(3):598-606. [pmid: 25557932].
37 Xie J, Poole EM, Terry KL, et al. A prospective cohort study of dietary indices and incidence of epithelial ovarian cancer. J Ovarian Res. 2014;7:112. [pmid: 25477244].
38 Reedy J, Krebs-Smith SM, Miller PE, et al. Higher diet quality is associated with decreased risk of all-cause, cardiovascular disease, and cancer mortality among older adults. J Nutr. 2014;144(6):881-889. [pmid: 24572039].
39 Lopez-Garcia E, Rodriguez-Artalejo F, Li TY, et al. The Mediterranean-style dietary pattern and mortality among men and women with cardiovascular disease. Am J Clin Nutr. 2014;99(1):172-180. [pmid: 24172306].
40 Li WQ, Park Y, Wu JW, et al. Index-based dietary patterns and risk of head and neck cancer in a large prospective study. Am J Clin Nutr. 2014;99(3):559-566. [pmid: 24401718].
41 Kenfield SA, DuPre N, Richman EL, Stampfer MJ, Chan JM, Giovannucci EL. Mediterranean diet and prostate cancer risk and mortality in the Health Professionals Follow-up Study. Eur Urol. 2014;65(5):887-894. [pmid: 23962747].
42 George SM, Ballard-Barbash R, Manson JE, et al. Comparing indices of diet quality with chronic disease mortality risk in postmenopausal women in the Women's Health Initiative Observational Study: evidence to inform national dietary guidance. Am J Epidemiol. 2014;180(6):616-625. [pmid: 25035143].
43 Cuenca-Garcia M, Artero EG, Sui X, Lee DC, Hebert JR, Blair SN. Dietary indices, cardiovascular risk factors and mortality in middle-aged adults: findings from the Aerobics Center Longitudinal Study. Ann Epidemiol. 2014;24(4):297-303. [pmid: 24529647].
44 Ax E, Garmo H, Grundmark B, et al. Dietary patterns and prostate cancer risk: report from the population based ULSAM cohort study of Swedish men. Nutr Cancer. 2014;66(1):77-87. [pmid: 24325263].
45 Mursu J, Steffen LM, Meyer KA, Duprez D, Jacobs DR Jr. Diet quality indexes and mortality in postmenopausal women: the Iowa Women's Health Study. Am J Clin Nutr. 2013;98(2):444-453. [pmid: 23783291].
46 Link AR, Gammon MD, Jacobson JS, et al. Use of self-care and practitioner-based forms of complementary and alternative medicine before and after a diagnosis of breast cancer. Evid Based Complement Alternat Med. 2013:301549. Epub 2013 Aug 12. [pmid: 23997792].
47 Li WQ, Park Y, Wu JW, et al. Index-based dietary patterns and risk of esophageal and gastric cancer in a large cohort study. Clin Gastroenterol Hepatol. 2013;11(9):1130-1136. [pmid: 23591281].
48 Kyro C, Skeie G, Loft S, et al. Adherence to a healthy Nordic food index is associated with a lower incidence of colorectal cancer in women: the Diet, Cancer and Health cohort study. Br J Nutr. 2013;109(5):920-927. [pmid: 22874538].
49 Gnagnarella P, Maisonneuve P, Bellomi M, et al. Red meat, Mediterranean diet and lung cancer risk among heavy smokers in the COSMOS screening study. Ann Oncol. 2013;24(10):2606-2611. [pmid: 23956193].
50 Couto E, Sandin S, Lof M, Ursin G, Adami HO, Weiderpass E. Mediterranean dietary pattern and risk of breast cancer. PLoS One. 2013;8(2):e55374. [pmid: 23390532].
51 Buckland G, Travier N, Cottet V, et al. Adherence to the Mediterranean diet and risk of breast cancer in the European Prospective Investigation into Cancer and Nutrition cohort study. Int J Cancer. 2013;132(12):2918-2927. [pmid: 23180513].
52 Bosire C, Stampfer MJ, Subar AF, et al. Index-based dietary patterns and the risk of prostate cancer in the NIH-AARP diet and health study. Am J Epidemiol. 2013;177(6):504-513. [pmid: 23408548].
53 Bamia C, Lagiou P, Buckland G, et al. Mediterranean diet and colorectal cancer risk: results from a European cohort. Eur J Epidemiol. 2013;28(4):317-328. [pmid: 23579425].
54 Tognon G, Nilsson LM, Lissner L, et al. The Mediterranean diet score and mortality are inversely associated in adults living in the subarctic region. J Nutr. 2012;142(8):1547-1553. [pmid: 22739377].
55 Menotti A, Alberti-Fidanza A, Fidanza F, Lanti M, Fruttini D. Factor analysis in the identification of dietary patterns and their predictive role in morbid and fatal events. Public Health Nutr. 2011;15(7):1232-1239. [pmid: 22166270].
56 Chiuve SE, Fung TT, Rimm EB, et al. Alternative dietary indices both strongly predict risk of chronic disease. J Nutr. 2012;142(6):1009-1018. [pmid: 22513989].
57 Couto E, Boffetta P, Lagiou P, et al. Mediterranean dietary pattern and cancer risk in the EPIC cohort. British Journal of Cancer. 2011;104(9):1493-1499. [pmid: 21468044].
58 Cade JE, Taylor EF, Burley VJ, Greenwood DC. Does the Mediterranean dietary pattern or the Healthy Diet Index influence the risk of breast cancer in a large British cohort of women?. Eur J Clin Nutr. 2011;65(8):920-928. [pmid: 21587285].
59 Fung TT, Hu FB, Wu K, Chiuve SE, Fuchs CS, Giovannucci E. The Mediterranean and Dietary Approaches to Stop Hypertension (DASH) diets and colorectal cancer. Am J Clin Nutr. 2010;92(6):1429-1435. [pmid: 21097651].
60 Agurs-Collins T, Rosenberg L, Makambi K, Palmer JR, Adams-Campbell L. Dietary patterns and breast cancer risk in women participating in the Black Women's Health Study. Am J Clin Nutr. 2009;90(3):621-628. [pmid: 19587089].
61 Reedy J, Mitrou PN, Krebs-Smith SM, et al. Index-based dietary patterns and risk of colorectal cancer: the NIH-AARP Diet and Health Study. Am J Epidemiol. 2008;168(1):38-48. [pmid: 18525082].
62 Sant M, Allemani C, Sieri S, et al. Salad vegetables dietary pattern protects against HER-2-positive breast cancer: a prospective Italian study. Int J Cancer. 2007;121(4):911-914. [pmid: 17455245].
63 Lagiou P, Trichopoulos D, Sandin S, et al. Mediterranean dietary pattern and mortality among young women: a cohort study in Sweden. Br J Nutr. 2006;96(2):384-392. [pmid: 16923235].
64 Kesse E, Clavel-Chapelon F, Boutron-Ruault MC. Dietary patterns and risk of colorectal tumors: a cohort of French women of the National Education System (E3N). Am J Epidemiol. 2006;164(11):1085-1093. [pmid: 16990408].
65 Fung TT, Hu FB, McCullough ML, Newby PK, Willett WC, Holmes MD. Diet quality is associated with the risk of estrogen receptor-negative breast cancer in postmenopausal women. J Nutr. 2006;136(2):466-472. [pmid: 16424129].
66 Velie EM, Schairer C, Flood A, He JP, Khattree R, Schatzkin A. Empirically derived dietary patterns and risk of postmenopausal breast cancer in a large prospective cohort study. Am J Clin Nutr. 2005;82(6):1308-1319. [pmid: 16332665].
67 Michaud DS, Skinner HG, Wu K, et al. Dietary patterns and pancreatic cancer risk in men and women. J Natl Cancer Inst. 2005;97(7):518-524. [pmid: 15812077].
68 Kim HJ, Kim MK, Chang WK, Choi HS, Choi BY, Lee SS. Effect of nutrient intake and Helicobacter pylori infection on gastric cancer in Korea: a case-control study. Nutr Cancer. 2005;52(2):138-146. [pmid: 16201845].
69 Adebamowo CA, Hu FB, Cho E, Spiegelman D, Holmes MD, Willett WC. Dietary patterns and the risk of breast cancer. Ann Epidemiol. 2005;15(10):789-795. [pmid: 16257363].
70 Sieri S, Krogh V, Pala V, et al. Dietary patterns and risk of breast cancer in the ORDET cohort. Cancer Epidemiol Biomark Prev. 2004;13(4):567-572.
71 Knoops KT, de Groot LC, Kromhout D, et al. Mediterranean diet, lifestyle factors, and 10-year mortality in elderly European men and women: the HALE project. JAMA. 2004;292(12):1433-1439. [pmid: 15383513].
72 Dixon LB, Balder HF, Virtanen MJ, et al. Dietary patterns associated with colon and rectal cancer: results from the Dietary Patterns and Cancer (DIETSCAN) Project. Am J Clin Nutr. 2004;80(4):1003-1011. [pmid: 15447912].
73 Terry P, Suzuki R, Hu FB, Wolk A. A prospective study of major dietary patterns and the risk of breast cancer. Cancer Epidemiol Biomark Prev. 2001;10(12):1281-1285.
74 Mannisto S, Dixon LB, Balder HF, et al. Dietary patterns and breast cancer risk: results from three cohort studies in the DIETSCAN project. Cancer Causes Control. 2005;16(6):725-733. [pmid: 16049811].
75 Buckland G, Ros MM, Roswall N, et al. Adherence to the Mediterranean diet and risk of bladder cancer in the EPIC cohort study. Int J Cancer. 2014;134(10):2504-2511. [pmid: 24226765].
76 Cherbuin N, Anstey KJ. The Mediterranean diet is not related to cognitive change in a large prospective investigation: the PATH Through Life study. Am J Geriatr Psychiatry. 2012;20(7):635-639. [pmid: 21937919].
77 Feart C, Samieri C, Rondeau V, et al. Adherence to a Mediterranean diet, cognitive decline, and risk of dementia. JAMA. 2009;302(6):638-648. [pmid: 19671905].
78 Gardener S, Gu Y, Rainey-Smith SR, et al. Adherence to a Mediterranean diet and Alzheimer's disease risk in an Australian population. Transl Psychiatry Psychiatry. 2012;2:e164.
79 Gardener SL, Rainey-Smith SR, Barnes MB, et al. Dietary patterns and cognitive decline in an Australian study of ageing. Mol Psychiatry. 2015;20(7):860-866. [pmid: 25070537].
80 Kesse-Guyot E, Andreeva VA, Lassale C, et al. Mediterranean diet and cognitive function: a French study. Am J Clin Nutr. 2013;97(2):369-376. [pmid: 23283500].
81 Psaltopoulou T, Kyrozis A, Stathopoulos P, Trichopoulos D, Vassilopoulos D, Trichopoulou A. Diet, physical activity and cognitive impairment among elders: the EPIC-Greece cohort (European Prospective Investigation into Cancer and Nutrition). Public Health Nutr. 2008;11(10):1054-1062. [pmid: 18205988].
82 Roberts RO, Geda YE, Cerhan JR, et al. Vegetables, unsaturated fats, moderate alcohol intake, and mild cognitive impairment. Dement Geriatr Cogn Disord. 2010;29(5):413-423. [pmid: 20502015].
83 Samieri C, Grodstein F, Rosner BA, et al. Mediterranean diet and cognitive function in older age. Epidemiology. 2013;24(4):490-499. [pmid: 23676264].
84 Samieri C, Okereke OI, E Devore E, Grodstein F. Long-term adherence to the Mediterranean diet is associated with overall cognitive status, but not cognitive decline, in women. J Nutr. 2013;143(4):493-499. [pmid: 23365105].
85 Scarmeas N, Luchsinger JA, Schupf N, et al. Physical activity, diet, and risk of Alzheimer disease. JAMA. 2009;302(6):627-637. [pmid: 19671904].
86 Scarmeas N, Stern Y, Mayeux R, Luchsinger JA. Mediterranean diet, Alzheimer disease, and vascular mediation. Arch Neurol. 2006;63(12):1709-1717. [pmid: 17030648].
87 Scarmeas N, Stern Y, Mayeux R, Manly JJ, Schupf N, Luchsinger JA. Mediterranean diet and mild cognitive impairment. Arch Neurol. 2009;66(2):216-225. [pmid: 19204158].
88 Scarmeas N, Stern Y, Tang MX, Mayeux R, Luchsinger JA. Mediterranean diet and risk for Alzheimer's disease. Ann Neurol. 2006;59(6):912-921. [pmid: 16622828].
89 Tangney CC, Kwasny MJ, Li H, Wilson RS, Evans DA, Morris MC. Adherence to a Mediterranean-type dietary pattern and cognitive decline in a community population. Am J Clin Nutr. 2011;93(3):601-607. [pmid: 21177796].
90 Tangney CC, Li H, Wang Y, et al. Relation of DASH- and Mediterranean-like dietary patterns to cognitive decline in older persons. Neurology. 2014;83(16):1410-1416. [pmid: 25230996].
91 Wengreen H, Munger RG, Cutler A, et al. Prospective study of Dietary Approaches to Stop Hypertension- and Mediterranean-style dietary patterns and age-related cognitive change: the Cache County Study on Memory, Health and Aging. Am J Clin Nutr. 2013;98(5):1263-1271. [pmid: 24047922].
92 Koyama A, Houston DK, Simonsick EM, et al. Association between the Mediterranean diet and cognitive decline in a biracial population. J Gerontol A Biol Sci Med Sci. 2015;70(3):354-359. [pmid: 24994847].
93 Hu Y, Costenbader KH, Gao X, Hu FB, Karlson EW, Lu B. Mediterranean diet and incidence of rheumatoid arthritis in women. Arthritis Care Res. 2015;67(5):597-606.
94 Burr ML, Ashfield-Watt PA, Dunstan FD, et al. Lack of benefit of dietary advice to men with angina: results of a controlled trial. Eur J Clin Nutr. 2003;57(2):193-200. [pmid: 12571649].
95 de Lorgeril M, Renaud S, Mamelle N, et al. Mediterranean alpha-linolenic acid-rich diet in secondary prevention of coronary heart disease. Lancet. 1994;343(8911):1454-1459. [pmid: 7911176].
96 de Lorgeril M, Salen P, Martin JL, et al. Effect of a Mediterranean type of diet on the rate of cardiovascular complications in patients with coronary artery disease. Insights into the cardioprotective effect of certain nutriments. J Am Coll Cardiol. 1996;28(5):1103-1108. [pmid: 8890801].
97 de Lorgeril M, Salen P, Martin JL, Monjaud I, Boucher P, Mamelle N. Mediterranean dietary pattern in a randomized trial: prolonged survival and possible reduced cancer rate. Arch Intern Med. 1998;158(11):1181-1187. [pmid: 9625397].
98 Singh RB, Dubnov G, Niaz MA, et al. Effect of an Indo-Mediterranean diet on progression of coronary artery disease in high risk patients (Indo-Mediterranean Diet Heart Study): a randomised single-blind trial. Lancet. 2002;360(9344):1455-1461. [pmid: 12433513].
99 Singh RB, Rastogi SS, Verma R, et al. Randomised controlled trial of cardioprotective diet in patients with recent acute myocardial infarction: results of one year follow up. BMJ. 1992;304(6833):1015-1019. [pmid: 1586782].
100 Singh RB, Rastogi SS, Sircar AR, Mehta PJ, Sharma KK. Dietary strategies for risk-factor modification to prevent cardiovascular diseases. Nutrition. 1991;7(3):210-214. [pmid: 1666320].
101 McKellar G, Morrison E, McEntegart A, et al. A pilot study of a Mediterranean-type diet intervention in female patients with rheumatoid arthritis living in areas of social deprivation in Glasgow. Ann Rheum Dis. 2007;66(9):1239-1243. [pmid: 17613557].
102 Skoldstam L, Hagfors L, Johansson G. An experimental study of a Mediterranean diet intervention for patients with rheumatoid arthritis. Ann Rheum Dis. 2003;62(3):208-214. [pmid: 12594104].
103 White C. Suspected research fraud: difficulties of getting at the truth. BMJ. 2005;331(7511):281-288. [pmid: 16052022].
104 Fung TT, Kashambwa R, Sato K, et al. Post diagnosis diet quality and colorectal cancer survival in women. PLoS One. 2014;9(12):e115377. [pmid: 25506700].
105 Kim EHJ, Willet WC, Fung T, Rosner B, Holmes MD. Diet qualityindices and postmenopausal breast cancer survival. Nutr Cancer. 2011;63(3):381-388. [pmid: 21462090].
106 Kroenke CH, Fung TT, Hu FB, Holmes MD. Dietary patterns and survival after breast cancer diagnosis. J Clin Oncol. 2005;23(36):9295-9303. [pmid: 16361628].
107 Kwan ML, Weltzien E, Kushi LH, Castillo A, Slattery ML, Caan BJ. Dietary patterns and breast cancer recurrence and survival among women with early-stage breast cancer. J Clin Oncol. 2009;27(6):919-926. [pmid: 19114692].
108 Meyerhardt JA, Niedzwiecki D, Hollis D, et al. Association of dietary patterns with cancer recurrence and survival in patients with stage III colon cancer. JAMA. 2007;298(7):754-764. [pmid: 17699009].
109 Vrieling A, Buck K, Seibold P, et al. Dietary patterns and survival in German postmenopausal breast cancer survivors. Br J Cancer. 2013;108(1):188-192. [pmid: 23169282].
110 Yang M, Kenfield SA, Van Blarigan EL, et al. Dietary patterns after prostate cancer diagnosis in relation to disease-specific and total mortality. Cancer Prev Res. 2015;8(6):545-551.
111 Elmer PJ, Obarzanek E, Vollmer WM, et al. Effects of comprehensive lifestyle modification on diet, weight, physical fitness, and blood pressure control: 18-month results of a randomized trial. Ann Intern Med. 2006;144(7):485-495. [pmid: 16585662].
112 Mathers CD, Loncar D. Projections of global mortality and burden of disease from 2002 to 2030. PLoS Med. 2006;3(11):e442. [pmid: 17132052].
113 Women's Health Initiative Study Group. Dietary adherence in the Women's Health Initiative Dietary Modification Trial. J Am Diet Assoc. 2004;104(4):654-658. [pmid: 15054353].
114 Logan KJ, Woodside JV, Young IS, McKinley MC, Perkins-Porras L, McKeown PP. Adoption and maintenance of a Mediterranean diet in patients with coronary heart disease from a Northern European population: a pilot randomised trial of different methods of delivering Mediterranean diet advice. J Hum Nutr Diet. 2010;23(1):30-37. [pmid: 19788708].
115 Zazpe I, Sanchez-Tainta A, Estruch R, et al. A large randomized individual and group intervention conducted by registered dietitians increased adherence to Mediterranean-type diets: the PREDIMED study. J Am Diet Assoc. 2008;108(7):1134-1144. [pmid: 18589019].